# Methods

## Topic Refinement

The topic of this report and preliminary Key Questions (KQs) were developed through a process involving the public, the Scientific Resource Center for the Effective Health Care program of the Agency for Healthcare Research and Quality (AHRQ), and various stakeholder groups. The KQs developed as a result of this process were posted on AHRQ’s website for public comment in October 2012 for 4 weeks and revised as needed. Study, patient, intervention, eligibility criteria, and outcomes, were refined and agreed upon through discussions between the McMaster University Evidence-based Practice Center (EPC), the Technical Expert Panel (TEP) members, the AHRQ Task Order Officer (TOO), and comments received from the public posting of the Key Questions. (www.effectivehealthcare.ahrq.gov/ehc/products/371/811/Tinnitus_Protocol_20120222.pdf).

The EPC convened a group of experts in the fields of Tinnitus and systematic review methods to form the TEP. Members of the TEP provided input to help interpret the KQs guiding this review, identify important issues, and define parameters for the review of evidence.

## Search Strategy

The search was conducted in six databases: MEDLINE^®^, EMBASE^®^, Cochrane Central, PsycINFO^®^, AMED^©^, and CINAHL^®^. These databases were chosen because they represent the best sources for a broad range of high-quality literature relevant to this topic. In particular, Embase^®^ seems to index a wider range of audiology journals than MEDLINE^®^, including Audiological Medicine. AMED^®^ and CINAHL^®^ have been included because of the inclusion of complementary and alternative medicine therapies in the interventions considered in this review.

Tinnitus is well indexed in the medical bibliographic databases, and there were few alternative terms that needed to be included in the search strategy. The search strategy used combinations of controlled vocabulary (medical subject headings (MeSH^®^), keywords) and text words. The search was restricted to human-focused studies (specifically removing those results that only include animal data), and certain citation types not included in this review were removed as part of the search (see Appendix A for detailed search strategy by database). The databases were searched from January 1970 to June 2012. The basic search strategy is listed below.

1. Tinnitus/or tinnitus.ti.
2. animals/not humans/
3. 1 not 2
4. limit 3 to English language
5. limit 4 to (case reports or comment or editorial or in vitro or interview or letter or newspaper article or webcasts)
6. 4 not 5

Citations meeting this search criteria were downloaded into Reference Manager^®^ 12 (Thomson Reuters, New York, NY) and then imported into a systematic review software program, DistillerSR (Evidence Partners Inc., Ottawa, Canada), for screening. Once in DistillerSR, citations were screened in duplicate by trained members of the synthesis team using the specified eligibility criteria for the review. Articles marked for inclusion by either team member proceeded to full text rating, which was also completed independently by two reviewers. All disagreements were resolved through discussions with the synthesis team, and inclusion results were reviewed by a third person.

In addition to the electronic database search, review of reference lists of eligible studies at full text screening was undertaken. Systematic reviews and meta-analyses were separately coded for retrieval during screening, and the reference lists were reviewed. Any potentially relevant citations were cross-checked within the citation database. Any references not found within the database were retrieved, added, and screened at full text.

### Grey Literature

Three types of grey literature sources were searched: regulatory agency Web sites, clinical trial databases, and conference sources. The regulatory information included the U.S Food and Drug Administration (FDA), Health Canada, and the European Medicines Agency. The clinical trial databases searched include: clinicaltrials.gov, clinicaltrialsregister.eu, metaRegister of Current Controlled Trials, Clinical Trial Registries, Clinical Study Results, and World Health Organization Clinical Trials. Conference papers were searched in the Conference Papers Index for the last 2 years only. This was to allow for the inclusion of studies that have been presented at conferences but have not yet had the chance to be published.

In addition, the Web sites of the following tinnitus-related organizations were searched for additional citations:

- The American Tinnitus Association
- The Association for Research in Otolaryngology
- American Academy of Audiology
- Emory University Tinnitus and Hyperacusis Center
- Tinnitus Research Initiative
- Deafness Research (United Kingdom)

The Scientific Resource Center also requested the Scientific Information Packages for drugs and devices and any missing relevant studies were added to the screening process.

## Criteria for Inclusion/Exclusion of Studies in the Review

Inclusion and exclusion criteria are based on the eligibility criteria from the PICOTS identified in Chapter 1, and are summarized below in Table 2. Based on input from the TEP indicating that the majority of available studies would be published in English-language journals, non-English-language publications were excluded.69,70 Included studies were randomized controlled trials (RCTs) or observational studies (e.g., cohort, case-control) with true control groups and provided sufficient detail about methods and results to enable use and aggregation of the data and results. Meta-analyses and systematic and narrative reviews were excluded, but reference lists were evaluated for potentially relevant citations. Case reports, case series, editorials, comments, letters, opinion pieces, conference proceedings and abstracts, books, and book chapters were excluded.

Table 2 Inclusion and exclusion criteria

Category | Inclusion Criteria | Exclusion Criteria
Population | KQ1: Adult (≥18 yrs) patients who visit healthcare practitioners with symptoms of tinnitus (e.g., ringing in the ears, whooshing sounds) KQ2 & 3: Adults (≥18 yrs) with a diagnosis of subjective idiopathic (nonpulsatile) tinnitus who are sufficiently bothered by tinnitus that they are seeking a treatment intervention | - Subjects <18 years of age; - Dx of pulsatile tinnitus; - Unilateral cases with specific medical Dx (e.g., paraganglioma, acoustic neuroma); - Tinnitus as side effect of drugs; - Nonhuman subjects
Interventions | KQ1: Direct observation or observation of sound with stethoscope; referral to a health professional with expertise on managing tinnitus (i.e., otolaryngologist, audiologist, neurologist, mental health professional); administration of scales/questionnaires to assess severity (e.g., THI, TRQ, TSI, VAS) KQ2: Any treatment/therapy used to reduce/help cope with tinnitus including but not limited to: Pharmacological; - Pharmacological treatments: Tricyclic antidepressants (e.g., amitriptyline, nortriptyline, trimipramine); selective serotonin-reuptake inhibitors (e.g., fluoxetine, paroxetine); other: trazodone, anxiolytics (e.g., alprazolam), vasodilators and vasoactive substances (e.g., prostaglandin E1), intravenous lidocaine; gabapentin, Botox (botulinum toxin type A), and pramipexole, Complementary and alternative medicine therapies: Gingko biloba extracts or other food supplements; Medical; - LLLT; - TMJ treatment: dental orthotics and self-care; surgery; - Transcranial magnetic stimulation; - Hyperbaric oxygen therapy; - Complementary and alternative medicine therapies: acupuncture; diet, lifestyle, and sleep modifications (e.g., caffeine avoidance, exercise); Sound Treatments/Technologies; - Hearing aids, cochlear implants, sound generators, maskers; - Neuromonics; Psychological/Behavioral; - CBT, biofeedback, education, relaxation therapies, PTM, TRT; Combination Therapies; - Any combination of tinnitus interventions (e.g., pharmacological treatment with DBT); KQ3: Any treatment/therapy used to reduce/help/cope with tinnitus including but not limited to those described in KQ2 | KQ1: Nondirect observations KQ2: No exclusions for interventions KQ3: No exclusions for interventions
Comparators | KQ1: Different clinical evaluation methods used to characterize a diagnosis and measure severity of subjective idiopathic tinnitus KQ2:; - Inactive controls (including placebo; no treatment; wait list; sham interventions); - Active controls (including treatment as usual; other intervention/treatments); KQ3:; - Prognostic factors: length of time to treatment after onset, audiological factors (e.g., degree and type of hearing loss, hyperacusis, loudness tolerance, masking criteria), head injury, anxiety symptoms, mental health disorders, and duration of tinnitus.; - Patient characteristics: age, sex, race, medical or mental health comorbidities, socioeconomic factors, noise exposure (environmental, recreational, work-related (including active and past military duty, and occupational hazards)), involvement in litigation, third-party coverage; Symptom characteristics: origin/presumed etiology of tinnitus, tinnitus duration since onset, subcategory of tinnitus, severity of tinnitus | KQ1: No exclusions KQ2: No exclusions KQ3: No exclusions
Comparators | KQ1: Different clinical evaluation methods used to characterize a diagnosis and measure severity of subjective idiopathic tinnitus KQ2:; - Inactive controls (including placebo; no treatment; wait list; sham interventions); - Active controls (including treatment as usual; other intervention/treatments); KQ3:; - Prognostic factors: length of time to treatment after onset, audiological factors (e.g., degree and type of hearing loss, hyperacusis, loudness tolerance, masking criteria), head injury, anxiety symptoms, mental health disorders, and duration of tinnitus.; - Patient characteristics: age, sex, race, medical or mental health comorbidities, socioeconomic factors, noise exposure (environmental, recreational, work-related (including active and past military duty, and occupational hazards)), involvement in litigation, third-party coverage; - Symptom characteristics: origin/presumed etiology of tinnitus, tinnitus duration since onset, subcategory of tinnitus, severity of tinnitus | KQ1: No exclusions KQ2: No exclusions KQ3: No exclusions
Outcomes | KQ1: Final outcome: No treatment; need for specialized treatment (e.g., audiology, otolaryngology, neurology, mental health care); extent of intervention KQ2: Tinnitus-specific Quality of Life, Sleep disturbance, depression symptoms, subjective loudness, Global quality of life, tinnitus severity, adverse effects (worsening of tinnitus, sedation, surgical complications, other treatment emergent events) KQ3: Time until improvement, sleep disturbance, discomfort, anxiety symptom, depression symptoms, subjective loudness, quality of life, return to “normal” work, adverse effects (worsening of tinnitus, sedation, surgical complications) | Studies where outcomes were reported on non-numeric scales (such as loudness in dB).
Publication languages | English | Non-English
Study design | All KQs:; - RCTs or non-randomized (quasi-randomized, controlled clinical studies) with at least one comparator group; - Original research studies must provide sufficient detail about methods and results to enable use and aggregation of the data and results; - Relevant outcomes must be able to be extracted from data in the papers; - Controlled experimental studies (manipulation of treatment) | All KQs: Studies where:; - Only scatter plots and bar graphs (no numerical data) presented; - Effect size could not be estimated (i.e., only p values reported with no outcome measure data); - Outcome results reported results in the form of improvement (percent) or responder versus non-responder; - If the studies did not state a priori that the results would be reported in this way; KQ2:; - Cross-over studies that did not report first period data; - Observational studies without comparators (case reports, case series, before-after studies); - Observational studies without interventions (case-control studies, population cohort studies); - Systematic reviews and narrative reviews (evaluated for reference list review); - Editorials, comments, letters, opinion pieces, and abstracts
Setting | Primary care; specialty care (audiology, otolaryngology, neurology, mental health) | No exclusions
Other criteria | Studies must address one or more of the following for tinnitus: KQ1: Instruments used to identify patients for further evaluation or treatment KQ2: Treatment modality KQ3: Predictors of treatment outcomes (prognostic factors, patient characteristics, and symptom characteristics)

Abbreviations: DBT = cognitive behavioral therapy; dB = decibals; Dx = diagnosis; KQ = Key Question; LLLT = low level laser LL treatment; PTM = progressive tinnitus management; RCT = randomized controlled trial; THI = Tinnitus Handicap Inventory; TMJ = temporomandibular joint; TRQ = Tinnitus Reaction Questionnaire; TRT = tinnitus retraining therapy; TSI = Tinnitus Severity Index; VAS = visual analogue scale; yrs = years

At the full text screening level, articles were excluded for any of the previously cited reasons. They were also excluded for KQ2 and KQ3 if there was not a treatment intervention for tinnitus (e.g., prevalence studies, studies to determine effects of tinnitus on brain wave patterns or memory); if tinnitus was somatic (e.g., the result of middle ear pathologies or ototoxicity, or was pulsatile in nature), or the intervention was a stapedectomy or tympanoplasty; and/or certain study designs/methods of presenting data (e.g., only determined various effects, a nonrandomized head-to-head design, or did not give sufficient detail of data for analyses).

Refer to Appendix B for Screening and Data Extraction Forms and the accompanying help sheets.

## Data Extraction

The Evidence-based Practice Center staff members and clinical experts conducting this review jointly developed the evidence table that was used to abstract data from the studies (Appendix B). The table was designed to provide enough information to enable readers to understand the studies, including types of study design, descriptions of the study populations (for applicability), description of the intervention, appropriateness of comparison groups, validated questionnaire measures used, baseline and outcome data on constructs of interest, and followup conducted. Details of the patient population extracted included age, sex, duration of tinnitus, severity of tinnitus, audiological factors, and comorbidities. Data were also collected about the site where study participants were recruited and the professional setting (primary care, audiology, otolaryngology, neurology, or mental health). In addition to outcomes related to treatment effectiveness, all available data on harms or adverse effects of treatments were extracted.

To ensure quality control, the team extracted several articles into the evidence table and then reconvened as a group to discuss the utility of the table design. This process was repeated until it was decided that the table included the appropriate categories to gather the information contained in the articles. All team members shared the task of initially entering information into the evidence table. Another team member then reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The full research team met regularly during the article abstraction period to discuss any conflicts or issues related to the data abstraction process.

## Assessment of Methodological Risk of Bias of Individual Studies

To assess individual study quality, methods recommended by AHRQ for its EPC Program in Chapter 5 of the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter Methods Guide) were employed.71 Two raters assessed the quality of individual studies using standardized quality assessment tools. Inconsistency among raters was minimized by providing standardized instructions and clear decision rules. Disagreement between raters was resolved by consensus.

Risk of bias assessment tools consist of five domains: population, outcome, exposure, statistical analysis, and, for RCTs, randomization, blinding, and withdrawals. These domains were adapted from the Newcastle-Ottawa quality assessment scales for case-control studies and cohort studies72 and the Jadad scale for RCTs.73 Additional items were needed for the Newcastle Ottawa Scale (NOS) to describe the population for cohort studies (2 items) and three additional items for the Jadad scale. Each quality item was be scored as yes, no, or unsure. An answer of “no” corresponds to a high risk of bias, “unsure” corresponds to a possible or unclear risk of bias, and “yes” corresponds to a low risk of bias. For each quality item, the responses were graphed and problem areas discussed. An overall quality score was not calculated.

### Assessing Applicability

Applicability may be affected by differences between what occurs in research and what happens in everyday clinical practice. Applicability was assessed in accordance with AHRQ standards.74 The basis for applicability assessment of findings was limited to the populations, interventions, outcomes, and settings described in the protocol and the PICOTS. Comorbidities, age of subjects, location where study subjects were recruited, specific treatment provider, and length of time to treatment are examples of a priori factors that may limit applicability. Subgroup factors that may cause or explain heterogeneity of treatment effect may include patients provided with proper audiological care before tinnitus treatment, psychological and hearing loss comorbidities, and subtyping by prognostic, patient, and symptom characteristics that may interact with treatment outcome.

## Data Synthesis

### Qualitative Synthesis

Study results are presented in three sections based on the three KQs. All included studies have been summarized in narrative form, and summary tables have been created showing key study characteristics, methodological limitations, and any other important aspect related to each Key Question.

### Quantitative Synthesis

The outcomes of interest in each study were reported using different outcome measures on a continuous scale. With the intention to perform meta-analysis using continuous data, immediate post-treatment data (mean, standard deviation, and sample size) for each treatment group were utilized. The DerSimonian and Laird random effects models with inverse variance method were selected to generate the summary measures of effect in the form of standardized mean difference (SMD) for each outcome. The SMD was selected as a summary statistic because the studies in this systematic review often assessed the same outcome domains using a variety of measures and scales. In this situation, it was necessary to standardize the results of the studies before they could be compared across studies or combined in a quantitative synthesis. SMD was calculated using change from baseline data, (i.e., mean difference between pre-treatment (baseline) and post-treatment (final/endpoint) scores, along with its standard deviation for both intervention and control groups). In studies where change from baseline data was not reported for treatment groups, the mean difference was calculated from pre- and post-treatment scores provided and standard deviation was computed using the following equation:

S D_C h a n g e_ = sqrt(S D_B a s e l i n e_^2^ + S D_F i n a l_^2^ - ( 2 × C o r r × S D_B a s e l i n e_ × S D_F i n a l_ )) The equation shows the computation method for estimating standard deviation for mean change score between baseline and final outcome values. It is calculated as; square root of final value obtained from sum of square of baseline and final mean standard deviations, minus, two multiplied with correlation between baseline and final mean values along with standard deviations of baseline and final mean value

Where, SD_change_ = Standard deviation of mean difference (pre and post treament),

SD_Baseline_ = Standard deviation if pre-treatment score,

SD_Final_ = Standard deviation of post-treatment score,

Corr = Correlation between pre-treatment and post-treatment scores.

Based on evidence from existing literature, a correlation of 0.69 between pre-treatment scores (baseline) and post-treatment scores (final/endpoint) was used to calculate effect sizes.55,75 When sensitivity of potential correlation factors (0.0, 0.3, 0.5) was carried out, effect size estimates were found to be essentially unchanged. The Cochran’s Q (α=0.10) and I^2^ statistics were employed to quantify the statistical heterogeneity between studies, where p<0.10 indicates a high level of statistical heterogenity between studies. Sensitivity analyses were also performed on the type of intervention and study risk of bias, and by removing the studies with obvious between-group baseline imbalance to evaluate statistical stability and effect on statistical heterogeneity.

Although summary estimates for groupings of interventions were computed, we did not present the summary estimates because of the presence of high statistical heterogeneity or because of clinical heterogeneity (predominately related to differing dosage parameters, types of interventions, and study populations).

## Rating the Body of Evidence

The strength of evidence (SOE) was assessed for each KQ using the EPC method for intervention studies, which is based on methods developed by the GRADE Working Group.76 The judgments for the strength of evidence were determined by two of the study authors. The combination of authors varied with the section. The raters were experienced in undertaking systematic reviews or in audiology. Several domains of quality across studies may influence the overall SOE for these KQs, including:

1. Risk of bias (how the study design and conduct may have contributed to systematic error). This is judged as high, moderate, or low risk of bias.
2. Consistency of results (concerns homogeneity in direction and magnitude of results across different studies). In the context of intervention studies, this is the degree of heterogeneity of the summary effect size and can be evaluated with statistical tests of heterogeneity; these tests evaluate the null hypothesis that all studies in the meta-analysis have the same underlying magnitude of effect. When no summary effect size estimate is possible, then how widely the point estimate varies across studies and the degree of overlap between confidence intervals across studies was considered.75 The importance of the direction relative to the magnitude of the effect will be judged for each group of interventions and outcomes.77
3. Directness of the evidence (concerns whether the evidence being assessed reflects a single, direct link between the interventions of interest (tinnitus treatment) and the ultimate health outcome under consideration). Directness also applies to comparisons between interventions. For intervention studies, consideration should be given to how similar the test or the treatment is being used in practice reflecting the external validity or generalizability of the intervention.
4. Precision refers to the degree of certainty surrounding an effect estimate for each outcome (i.e., width of confidence intervals (CI)) for diagnostic accuracy outcomes, and treatment outcomes monitoring; this domain is related to study sample size and number of events).77
5. Other key domains (publication bias, dose-response association, and strength of association [i.e., magnitude of effect]) were all considered when relevant). From these dose-response and strength of association were not considered with respect to downgrading the evidence.

We assessed the SOE for the six outcomes of benefit: TSQoL, perceived loudness, sleep disturbance, anxiety symptoms, depression symptoms, and global quality of life, as well as outcomes of harm. The SOE was classified into four grades based on the AHRQ EPC Program approach: high, moderate, low, or insufficient76,78 as follows:

High quality SOE: Further research is very unlikely to change the confidence in the estimate of effect.

High SOE indicates that there are consistent findings (direction of effect and magnitude of effect) among 80% of the included comparative studies (RCT, CCT) with low risk of bias that are generalizable to the population in question. There are sufficient data (greater than 30 patients per intervention group for 80% of the included studies), with narrow confidence intervals. There are no known or suspected reporting or publication biases. Criteria for determining that there are no serious threats to validity are met in all domains (studies are at low risk of bias, consistent, direct, precise, and free of reporting and publication bias).

Moderate quality SOE: Further research is likely to have an important impact on the confidence in the estimate of effect and may change the estimate.

The majority of studies (80 % of included studies for each outcome) are at high or medium risk of bias or criteria for one of the other domains (consistency, precision, directness, or publication bias) is not met.

Low quality SOE: Further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate.

Criteria for two of the domains are not met or there are serious concerns in a single domain that affect the validity of the results.

Insufficient quality evidence: An estimate of effect is very uncertain. Criteria for at least three domains are not met.

No evidence: No comparative studies were identified that evaluated any the outcome of interest (since the quality is evaluated for each outcome).

Judgment of study limitations was anchored by the presence of a minimum of one RCT with a rating of ‘good’, or a rating of greater than 7 points from 12, indicating low risk of bias. For a number of interventions, there is only a single study result to be reported. For those, the consistency is unknown; similarly, for single studies the precision was rated as unknown.

Consistency for the remaining groupings was judged within the SOE tables, on the stability of the direction of the effect (favoring treatment or favoring control) based on the point estimate and the degree of overlap between confidence intervals.

For small sample sizes (30 or less per treatment group) and wide confidence intervals, all the intervention groupings were ranked as being imprecise.

For most interventions, fewer than 10 studies were eligible and as such publication bias could not be formally assessed using statistical approaches. The risk of publication bias is greater for reviews that are based on small randomized trials.79 Based on this potential risk, it was assumed that all intervention groupings were at risk in this systematic review and rated all groupings as “suspected” for publication bias.

## Peer Review and Public Comment

Experts in audiology, epidemiology, medical specialties, researchers and individuals representing stakeholder and user communities were invited to provide external peer review of this CER. The AHRQ TOO and an associate editor also provided comments on the report. The draft report was posted on the AHRQ website for 4 weeks to elicit public comment. All reviewer comments have been considered and the text revised. A disposition of comments report will be made available on the AHRQ website 3 months after the posting of the final report.