# Introduction

## Background

Tinnitus is a not a disease but rather a symptom or condition that can result from a number of underlying causes. In general, tinnitus is the perception of sound in the absence of an external auditory stimulus. The World Health Organization (WHO) describes tinnitus as a “symptom of hearing disorder characterized by the sensation of buzzing, ringing, clicking, pulsations, roaring or other noises in the ear.”1 Note that in the WHO International Classification of Diseases (ICD), tinnitus is coded as H93.1, which is not a specific ICD-10-CM diagnosis code and cannot be used to indicate a medical diagnosis.1

Tinnitus can disturb one’s day-to-day life in a number of ways including: causing distress and annoyance, disruption of sleep, anxiety symptoms, and depression symptoms. An estimated 16 percent of the American population (approximately 50 million people) experience tinnitus to some extent, with up to 16 million seeking medical help and 2 million being unable to lead a normal life.2 The prevalence of tinnitus increases with age and noise exposure.3,4 Similarly, hearing loss also increases with age and noise exposure. Although tinnitus is often associated with hearing loss, tinnitus can affect those who do not have clinically significant hearing loss and not all people who have hearing loss have tinnitus.

A variety of conditions and experiences can lead to tinnitus, but its exact physiology is still unknown. As a symptom, it may be associated with a number of conditions, including various auditory system pathologies, ranging from impacted wax to acoustic tumors, that warrant medical attention. According to the American Tinnitus Association (ATA), noise exposure is the largest attributed cause of tinnitus.5 People may acquire tinnitus and hearing loss when they are exposed to hazardous levels of industrial, recreational, or military noise. Tinnitus is the most common service-connected disability among U.S. veterans.2 Tinnitus is common in active-duty service members and veterans who have had traumatic brain injury (concussion) whether or not they have clinically significant hearing loss. There is growing concern that exposure to recreational noise may result in tinnitus in teenagers and young adults.6 Tinnitus can also be a side effect of potentially ototoxic drugs, ranging from aspirin taken to alleviate arthritic pain to aminoglycoside antibiotics and life-saving drugs used to treat cancer.7 These effects may be temporary but, especially with respect to aminoglycoside antibiotics and cancer chemotherapeutics, in particular cisplatin, can be permanent.

The severity of tinnitus experienced by patients may vary with, or depend upon, comorbidities. Tinnitus often co-occurs with hearing loss, and the bothersome effects of tinnitus may be alleviated by the use of hearing aids. Individuals who are dual sensory impaired (deaf and blind) may be confused by tinnitus because they do not have visual information to help them understand that their tinnitus is not an external sound. It is common for frequent tinnitus to be associated by mental health conditions, particularly generalized anxiety disorder.8–10 Although relatively little is known about tinnitus in younger people compared to what is known about middle-aged and older adults, the connection between tinnitus and mental health issues has been observed in teenagers with hearing loss.11 It is often regarded as a “chronic stressor, creating a vicious circle of stress and exacerbation of tinnitus.”12

### Classification

In both clinical and academic contexts, there is no consensus on the classification of tinnitus subcategories. A patient is often described as presenting with symptoms of either objective or subjective tinnitus. Objective tinnitus is perceptible by both patient and examiner. Other terms sometimes used for objective tinnitus are “somatosounds” or “somatic tinnitus” or “somatically modulated” tinnitus. Subjective tinnitus is perceptible only by the patient yet is not due to a hallucination. Both forms of tinnitus may or may not be idiopathic. Some investigators have argued that tinnitus should be classified by origin, either as somatic or neurophysiologic.13

In this classification by origin, somatic tinnitus is categorized as tinnitus with an underlying medical condition that creates internal acoustic mechanical sounds; e.g., the tinnitus has a vascular, muscular, respiratory, or temporomandibular joint (TMJ) origin.14 The sounds associated with somatic tinnitus (somatosounds) are most commonly pulsatile and may be heard by an observer either directly or through the use of a stethoscope or microphone. Somatic tinnitus requires an examination by a physician ear-specialist (e.g., otolaryngologist) who may be able to identify and treat the underlying condition.14 Although serious pathology is rarely a cause of tinnitus, pulsatile somatic tinnitus, tinnitus in only one ear (unilateral tinnitus), and tinnitus associated with vertigo require referral to a specialist.15

In this review, the term subjective idiopathic tinnitus will be used rather than neurophysiologic tinnitus because it is the term most commonly used in the current literature. As well, subjective idiopathic tinnitus is the most commonly diagnosed type of tinnitus.14 It is nonpulsatile, most often bilateral (perceived in both ears), and can only be heard by the patient and not directly observed by a physician, making it difficult to evaluate. Audiological protocols can be used to match the loudness and pitch of the tinnitus perceived by a patient to external sounds with known acoustical parameters.16 The “phantom sounds” heard by the patient with this type of tinnitus are attributed to a disruption in the neurological auditory pathway. With advances in neuroscience over the last decade, theories have shifted from an emphasis on peripheral to central auditory system involvement. There has also been a shift from conceptualizing tinnitus as a primarily auditory problem to be silenced, to considering it to be a psychological problem with which people can cope.17–19

### Measurement

It is essential to distinguish chronic tinnitus from temporary ear noises that would not be considered pathological (sudden, unilateral, tonal sounds that typically last for up to a minute before decaying). If the patient reports a constant or near-constant perception of tinnitus, the condition is identified as chronic. Typically, chronic tinnitus has a duration of at least 6 months.14

Various measures can be used to evaluate the presence and severity of the tinnitus.20 There are at least a dozen validated questionnaires for assessing the impact of tinnitus. Psychological grading scales can aid in the discrimination between clinically significant and nonsignificant degrees of tinnitus.21

Visual analog scales (VAS) are well known psychometric measures of subjective attitudes and characteristics. With a VAS, patients specify their level of agreement to a statement by indicating a position along a continuous line between two endpoints. The VAS can be used to assess loudness, pitch, and disturbance of the tinnitus.22 Tinnitus questionnaires contain a series of questions and patients select a response to each question from the given choices (usually a graded scale). Questionnaires, such as the Tinnitus Handicap Inventory (THI) and the Tinnitus Reaction Questionnaire (TRQ), are useful for grading tinnitus severity. However, these and most other tinnitus questionnaires are limited in that they were not designed nor validated to measure the effectiveness of tinnitus interventions.23 Such effectiveness is referred to as “responsiveness,” which emphasizes effect sizes, content validity, and response scaling that enables detection of change.24,25 The Tinnitus Functional Index (TFI) is a self-report questionnaire that has documented validity both for scaling the severity and negative impact of tinnitus and for measuring treatment-related changes in tinnitus. At this time it has not yet been used to evaluate comparative effectiveness of treatments.26

### Treatment

Following a medical examination, some patients with subjective idiopathic tinnitus may not receive a recommendation for further treatment, although the practitioner may provide information and assurance of the benign nature of the phenomenon. The complex relationships between tinnitus and a range of physical and mental health conditions have complicated the development and evaluation of intervention strategies. Comorbidities such as hearing loss, mental health problems, or sleep disorders may modulate the experience of tinnitus and direct treatment of those conditions may help to alleviate reactions to tinnitus. For cases of subjective idiopathic tinnitus in which a tinnitus-specific intervention is indicated, there is a wide range of interventions which can include (but are not limited to) pharmacological/food supplements, medical interventions, sound technologies, and psychological/behavioral interventions, as outlined below. These interventions may differ markedly in many dimensions, including the type of expertise required to deliver the treatment, the size and nature of the caseload being treated, and the costs associated with the method of delivery. Some interventions may be offered as programs designed to be cost-effective for large caseloads (e.g., internet CBT), while some may be extremely costly, individualized treatments suitable for only a small number of candidates and requiring a sophisticated technology and a high level of expertise on the part of the practitioner (e.g., cochlear implantation). It is also possible that multiple treatments be provided in combination or in a progressive approach, depending on the needs of the patient.

#### Pharmacological/Food Supplement Treatments

##### Pharmacological Treatments

No drug has been approved by the U.S. Food and Drug Administration (FDA) for treating tinnitus. However, various pharmacological treatments, including antidepressants, anxiolytics, vasodilators, and vasoactive substances, and intravenous lidocaine, have been prescribed for tinnitus.27–31 See Table 1 for examples. For the most part, these treatments have been indirect solutions because they focus on tinnitus-associated symptoms, such as depression symptoms, stress, or sleep disturbance.32 However, newer medications that attempt to modulate the central auditory pathways, such as pramipexole, are being investigated and may have promise for reducing the perception of tinnitus.33

Table 1 Some pharmacological treatments for tinnitus

Drug Class | Agents (Examples)
Antidepressants | Tricyclics: amitriptyline, nortriptyline, trimipramine Selective serotonin-reuptake inhibitors (SSRI): fluoxetine, paroxetine Other: trazodone
Anxiolytics | Alprazolam
Vasodilators/Vasoactive Substances | Prostaglandin E1
Other | Lidocaine, gabapentin, Botox^®^, pramipexole

Abbreviations: Botox = botulinum toxin type A; SSRI = selective serotonin-reuptake inhibitors

##### Food Supplements

Food supplements, such as Gingko biloba extracts, are also being used by patients with tinnitus. Extracts from Gingko biloba leaves are a traditional Chinese medicinal treatment used to increase blood flow, inhibit the platelet-activating factor, alter neuron metabolism, and prevent free radicals from damaging cell membranes. These improvements, as well as relief from tinnitus, are claimed by some to be attributed to the chemical compounds flavonoid and terpenoid, which are found within the Gingko biloba plant.34

#### Medical Interventions

##### Low Level Laser Treatments

Low level laser therapy (LLLT) has been used to treat tinnitus. Various rationales for using laser therapy have been proposed but not yet validated. It is suggested that laser irradiation can improve cell proliferation, increase blood flow in the inner ear canal, and activate cellular activities that repair hair cells.35 A variety of LLLT types have been used in patients and no specific dose recommendations exist regarding total energy density and method of application.

##### Temporomandibular Joint Treatment

Tinnitus, vertigo, and otalgia are symptoms that have been linked to temporomandibular joint (TMJ) disease.36 This disease consists of a collection of medical and dental conditions that affect the TMJ, masticulatory muscles, and/or the adjoining structures, causing pain and tenderness, most frequently felt in the jaw and the temple but also in the ear and surrounding area.37 Treatment can range from the use of dental orthotics and self-care instructions to surgery (in instances where injury to the jaw is the underlying cause).38

##### Transcranial Magnetic Stimulation

Transcranial magnetic stimulation (TMS) delivers an electro-magnetic field to the superficial cerebral cortices modulating the excitability in the area of the cerebral cortex believed to be associated with tinnitus.39 It has been shown to provide tinnitus relief in some cases, however, the underlying mechanisms of this effect are not yet understood, and no commercial treatment using this technique is currently available.40

##### Hyperbaric Oxygen Therapy

Hyperbaric oxygen therapy was reported to aid in the relief of tinnitus associated with sudden sensorineural hearing loss by improving the oxygen supply to the inner ear.41 This therapy, which is used to treat a variety of medical conditions, requires that the patient sit inside a pressured chamber containing an atmosphere of 100 percent oxygen, which increases the oxygen supply to body tissues.

##### Dietary Modifications

Limiting the intake of high-sodium foods, caffeine, chocolate, and other stimulants and avoiding refined sugars, artificial sweeteners, saturated and unsaturated fats, and monosodium glutamate are examples of diet modifications.42–44 This is not a comprehensive list.

##### Complementary and Alternative Medicine Therapies

Individuals seeking general information about tinnitus relief on the Internet will find a large array of complementary and alternative medicine (CAM) approaches proposed to relieve and even “cure” tinnitus. Numerous therapies that are considered CAM include, but are not limited to, the use of supplements or herbal remedies (e.g., gingko biloba, feverfew), mind and body approaches (e.g., meditation), manipulative and body-based practices (e.g., spinal manipulation, massage), whole body approaches (e.g., Traditional Chinese medicine, Aryuveda) and other non-allopathic therapies.45

#### Sound Technologies

##### Hearing Aids, Cochlear Implants, Maskers and Sound Generators

Hearing aids are one option for reducing reactions to tinnitus if the person also has hearing loss. Hearing aids can increase the overall level of ambient sound delivered to the patient, which can accomplish the objectives normally targeted for sound therapy. Some hearing aids have sound generators built in, which can be added to the amplified ambient sound. These devices are referred to as ‘combination instruments’ and are often considered as an option for patients who have hearing loss and bothersome tinnitus.46

Cochlear implants may reduce tinnitus because the tinnitus is masked by improving the perception of external sounds or through electrical stimulation of the auditory nerve, but until recently they were considered to be appropriate for use by only a very specific subset of patients (e.g., people who have bilateral profound sensorineural hearing loss).40 Very recently, cochlear implants have also been used successfully to reduce tinnitus in subjects with single-sided deafness, although this may be considered to be ‘off label’ use.47–49

Tinnitus masking was developed in the 1970s. The original purpose was to present a sufficiently intense signal matched to the characteristics of the individual’s tinnitus perception (e.g., frequency of tone, bandwidth of noise) that would cover up, or “mask,” the patient’s tinnitus. Currently, the purpose is to use sound to achieve a sense of relief from the stress or tension caused by tinnitus.50 This is done by using ear-level sound generators, which may be called “maskers,” that generate wideband noise. The word “masking” has created confusion—the method is now thought of as “sound-based relief.” Sound generators are also available as stationary tabletop devices. Sound generators (masking devices) have received Class II approval from the FDA. However, because they are considered to be “experimental, investigational, or unproven” therapies,50 they are generally not covered under health insurance plans.51

##### Neuromonics Tinnitus Treatment

Neuromonics Tinnitus Treatment is a combination of acoustic stimulation with a structured program of counseling and support by a clinician trained specifically in tinnitus rehabilitation.52 The acoustic component of the treatment is designed to provide “stimulation to auditory pathways deprived by hearing loss, engage positively with the limbic system, and allow intermittent, momentary tinnitus perception within a pleasant and relaxing stimulus, thereby facilitating desensitization to the tinnitus signal.”53 The device with headphones (likened to an MP3 player in appearance) delivers musical sound customized to the hearing loss of the individual. The typical treatment program lasts 6 months.

#### Psychological/Behavioral Treatments

In addition to its association with many physical health problems, tinnitus is also associated with many clinical and subclinical psychological health problems, both as a cause and consequence of tinnitus. For example, individuals with tinnitus may experience difficulties with attention and anxiety symptoms and those who are most distressed by tinnitus may be psychologically vulnerable.54 Treatments in this category enlist the use of psychological and/or behavioral interventions to reduce the negative consequences of tinnitus.

##### Cognitive Behavioral Therapy

Cognitive behavioral therapy (CBT) may effectively increase quality of life and the patient’s ability to deal with chronic tinnitus by restructuring thought patterns and habituating those patterns when the patient is reacting to tinnitus.55 It is suggested as one of the first recommendations a general practitioner should make according to the good-practice guidelines developed by the Department of Health in the United Kingdom.56 CBT encompasses a number of possible therapeutic procedures, including cognitive and/or behavioral techniques.57 Importantly, these interventions apply principles of learning and/or cognitive theories of affect, regulation, and behavior change.58 The overall goal is to change the psychological processes that are assumed to maintain or exacerbate the distress associated with tinnitus.

##### Tinnitus Retraining Therapy

Since its proposal in 1990, tinnitus retraining therapy (TRT) has been used to reprogram how a patient interprets the “tinnitus” sounds by combining sound therapy with directive counseling.59 A key feature of TRT is that sound is used, but for a different purpose than for masking. With TRT, sound is not intended to induce a sense of relief, but rather to create a background of sound to make the tinnitus less noticeable. TRT also involves fairly extensive counseling, which is based on the “neurophysiological model.”60 This model is used to help patients understand that tinnitus is a meaningless signal. The combination of sound therapy and counseling with TRT is designed to lead to habituation, such that the patient does not normally pay attention to the tinnitus and does not react to it when it does come into consciousness.59,60 Since TRT depends on both the use of sound and counseling, it spans two main categories of Psychological/Behavioral or Sound Technologies interventions. For the purposes of the present review, TRT is a unique sub-category and it has been situated in the Psychological/Behavioral category because the therapy specifically requires more than just the use of technology. TRT is most often compared to other treatments situated in the Psychological/Behavioral category rather than being compared to other technologies. However, one study61 involving TRT was placed in the Sound Technology category because it did involve a comparison between two technologies, sound generators and hearing aids, both used with TRT (i.e., the comparison did not pit TRT against an inactive control or another intervention that differed in terms of TRT itself). Also note that other interventions categorized as Psychological/Behavioral do not preclude the use of sound technology; for example individuals with hearing loss would be expected to try hearing aids to address communication needs whether or not there is an intention for hearing aids to provide relief from tinnitus.

##### Biofeedback, Education, and Relaxation Therapies

Biofeedback, education, and relaxation therapies aim to teach the patient to control or habituate to the perceived ringing and the subsequent distress. Biofeedback treatments are based on the presumption that the stress caused by tinnitus exaggerates a patient’s discomfort and that the patient can learn to control stress using biofeedback to monitor it. Biofeedback therapy for tinnitus involves listening to an audio signal produced by electromyography (EMG) of the frontalis muscle. EMG uses surface electrodes in the detection of muscle action potentials from underlying skeletal muscles that initiate muscle contractions.19

Educating patients about their tinnitus has been proposed to improve the management of tinnitus-related symptoms and the associated discomfort.19 It is especially important that patients are taught strategies to self-manage their tinnitus. No method currently exists to reduce or eliminate the sensation of tinnitus, thus patients need to learn how to help themselves for a potential lifetime of tinnitus management.13

Relaxation therapies also offer strategies to focus the patient’s attention away from the sound, aiming to psychologically alleviate stress responses to tinnitus.62 Although these therapies may not eliminate the tinnitus, they aim to improve quality of life through habituation to decrease consciousness of the noise. Relaxation therapies to address emotional responses to tinnitus are often combined with CBT.

##### Progressive Tinnitus Management

Progressive tinnitus management (PTM) is a methodology developed by the Veterans Health Administration (VHA). The VHA has endorsed PTM as the standard method of treatment at their medical centers.46 PTM uses elements of hearing aids, masking, TRT, and CBT. PTM is a stepped-care approach, based on education leading to self-efficacy, and it creates a framework for management that is flexible to accommodate differing requirements of clinicians and patients.46,63 A similar progressive stage treatment approach has recently been developed by others.64

## Scope and Key Questions

In a rehabilitative context, those with tinnitus are more likely than those without tinnitus to seek professional help and accept hearing aids, presumably because the combination of tinnitus and hearing loss increases disability,4,65 yet typical audiological interventions focus on the remediation of hearing loss rather than on treatments for tinnitus.4 Recent research findings from cognitive and auditory neuroscience studies have advanced knowledge of the biological underpinnings of some forms of tinnitus, while findings from clinical psychological studies have underscored the interactions among the auditory, cognitive, affective, and mental health issues that must be considered when designing and evaluating interventions to meet the needs of clinical subpopulations of patients. How some people “live with it” so much better than others is still not clear. Despite many available and promising treatments, there are no universally accepted therapies for managing tinnitus.

In 2008, the Tinnitus Research Initiative (TRI) created, and still continues to modify, a flowchart outlining steps for the diagnosis and management of tinnitus; however, this clinical protocol has yet to be adopted by any government or agency because the evidentiary base has not yet been evaluated.66 The usability of the TRI flowchart is limited as it reflects a biomedical approach: an approach that would be used by medical physicians, but not by providers such as audiologists or psychologists who implement behavioral methods. Organizations such as the ATA provide information on a variety of treatment options, but do not endorse or recommend any specific treatment. In 2009, the Department of Health in the United Kingdom issued the “Provision of Services for Adults with Tinnitus: A Good Practice Guide”56 for the commissioning of tinnitus services and for managing tinnitus from primary care onwards.67 The TRI flowchart and the United Kingdom Good Practice Guide reflect current best practices recommendations. Guidelines are currently not standardized in the United States, although the efforts and strategies of individual researchers appear in the research literature.14,68

As there is no “cure” for tinnitus, the absence of firm guidelines and management strategies demonstrates the need for further evaluation of current treatment options. This review aims to explore prognostic factors and strategies for the optimal management of tinnitus and to clarify the effectiveness of the various tinnitus treatments currently in use and their measurable outcomes. It also identifies gaps in the existing literature that will inform directions for future research.

### Key Questions and Eligibility Criteria

We identify the eligibility criteria for each Key Question (KQ) by describing inclusion and exclusion criteria for the population, intervention, comparators, outcomes, timing and setting (PICOTS).

#### KQ1 In patients with symptoms of tinnitus (e.g., ringing in the ears, whooshing sounds, etc.) what is the comparative effectiveness of methods used to identify patients for further evaluation or treatment?

##### Population(s)

Adult patients (18 and over) presenting with symptoms of tinnitus.

##### Interventions

Direct observation or observation of sound with stethoscope; referral to a health professional with expertise on managing tinnitus (e.g., otolaryngologist, audiologist, neurologist, mental health professional); administration of scales/or questionnaires to assess severity (e.g., THI, TRQ, TFI, VAS).

##### Comparators

Different clinical evaluation methods used to characterize a diagnosis and measure severity of subjective idiopathic tinnitus.

##### Outcomes

Final outcome: (1) No treatment; (2) need for specialized treatment (e.g., audiology, otolaryngology, neurology, mental health care); (3) extent of intervention.

##### Timing or Followup

No restrictions.

##### Setting

Primary care; specialty care (audiology, otolaryngology, neurology, mental health care).

Note: For KQ2 and KQ3, adults diagnosed with unilateral and/or pulsatile tinnitus need to be evaluated for other medical conditions, such as acoustic neuromas. This review will include only those cases in which a medically serious underlying pathology as the source of the tinnitus has already been ruled out.

#### KQ2 In adults with subjective idiopathic (nonpulsatile) tinnitus, what is the comparative effectiveness (and/or potential harms) of medical/surgical, sound treatment/technological, or psychological/behavioral interventions, including combinations of interventions?

##### Population(s)

Adult patients (18 and over) with a diagnosis of subjective idiopathic (nonpulsatile) tinnitus who are sufficiently bothered by tinnitus that they seek a treatment intervention.

##### Interventions

Any treatment/therapy used to reduce/help cope with tinnitus including but not limited to the following:

###### Pharmacological and Food Supplement Interventions

- Tricyclic antidepressants (e.g., amitriptyline, nortriptyline, trimipramine)
- Selective serotonin-reuptake inhibitors: fluoxetine and paroxetine
- Other: trazodone; anxiolytics (e.g., alprazolam); vasodilators and vasoactive substances (e.g., prostaglandin E1); intravenous lidocaine; gabapentin; Botox (botulinum toxin type A); and pramipexole
- Complementary and alternative medicine (CAM) therapies: Gingko biloba extracts; food supplements)

###### Medical Interventions

- Low level laser treatments (LLLT)
- TMJ treatment: dental orthotics and self-care; surgery
- Transcranial magnetic stimulation (TMS)
- Hyperbaric oxygen therapy
- Dietary modifications
- Complementary and alternative medicine (CAM) therapies that are not food supplements; acupuncture; diet, lifestyle, and sleep modifications (e.g., caffeine avoidance, exercise)
- Other related interventions that require administration by a clinician

###### Sound Treatments/Technologies Interventions

- Hearing aids
- Cochlear implants
- Sound generators/maskers (both wearable and stationary)
- Neuromonics

###### Psychological/Behavioral Interventions

- Cognitive behavioral therapy (CBT), coping training, psychotherapy
- Tinnitus retraining therapy (TRT)
- Biofeedback
- Education
- Relaxation therapies
- Progressive tinnitus management (PTM)

###### Combination Therapies

- Any combination of tinnitus interventions (e.g., pharmacological treatment with CBT)

##### Comparators

Inactive controls (including placebo; no treatment; wait list; sham interventions).

Active controls (including treatment as usual; other intervention/treatments).

##### Outcomes

###### Included Outcomes of Benefit

1. Tinnitus-specific Quality of Life
2. Sleep disturbance
3. Anxiety symptoms
4. Depression symptoms
5. Subjective loudness
6. Global Quality of Life

###### Included Adverse Effects

1. Worsening of tinnitus
2. Sedation
3. Surgical complications
4. All other treatment-emergent adverse effects reported for the various interventions

###### Excluded

Studies that reported outcomes on a non-numeric scale, such as loudness in decibels (dBs). No other outcomes were used to exclude studies.

##### Timing or Followup

No restrictions.

##### Setting

Primary care; specialty care (audiology, otolaryngology, neurology, and mental health care. Setting was not used as an exclusion criterion.

#### KQ3 For adults with subjective idiopathic tinnitus, what prognostic factors, patient characteristics, and/or symptom characteristics affect final treatment outcomes?

##### Population(s)

Adults (18 and over) with a diagnosis of subjective idiopathic tinnitus sufficiently bothered by tinnitus that they are seeking a treatment intervention.

##### Interventions

Any treatment/therapy used to reduce/help/cope with tinnitus including, but not limited to, those described in KQ2.

##### Comparators

- Prognostic factors: length of time to treatment after onset, audiological factors (degree and type of hearing loss, hyperacusis, loudness tolerance, masking criteria, etc.), head injury, anxiety symptoms, mental health disorders, and duration of tinnitus
- Patient characteristics: age, sex, race, medical or mental health comorbidities, socioeconomic factors, noise exposure (environmental, recreational and work-related (including active and past military duty, and occupational hazards)), involvement in litigation, third-party coverage
- Symptom characteristics: origin/presumed etiology of tinnitus, tinnitus duration since onset, subcategory of tinnitus, severity of tinnitus

##### Outcomes

###### Final Outcomes

1. Time until improvement
2. Sleep disturbance
3. Tinnitus-specific Quality of Life
4. Anxiety symptoms
5. Depression symptoms
6. Subjective loudness
7. Global Quality of Life
8. Return to “normal” work

###### Adverse Effects

1. Worsening of tinnitus
2. Sedation
3. Surgical complications
4. Any other treatment-emergent adverse effects.

##### Timing or Followup

No restrictions.

##### Setting

Primary care; specialty care (audiology, otolaryngology, neurology, mental health).

## Analytic Framework

Following consultation with key informants, the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer (TOO), and the investigative team, key research questions were developed. Figure 1 shows a flow diagram indicating the relationship between research questions in this Comparative Effectiveness Review (CER). This framework depicts the KQ as outlined in the PICOTS format (Population(s), Interventions, Comparators, Outcomes, Timing or followup, and Setting). The PICOTS components for each KQ are provided in full detail in Table 2.

Figure 1 Analytic framework

* Any studies that used the terms “annoyance” or “distress” to describe their outcomes were included under the category of “discomfort.”

** The outcome “severity” was added during data extraction. As severity was an outcome reported in 18 of 34 papers, it was decided that it should not be collapsed into any other outcome category.

Figure 1 depict+B23 the key questions within the context of the PICOTS described in this document. In general, the figure illustrates how the instruments used to evaluate tinnitus (KQ1) may lead to different treatment/intervention choices. The comparative effectiveness of treatment interventions (KQ2) may result in long-term outcomes such as changes in sleep disturbances, reduction in discomfort, anxiety, or depression or increased quality of life. The comparative effectiveness of treatment interventions as influenced by prognostic factors (e.g. length of time to treatment after onset; degree of hearing loss; head injury; anxiety; mental health disorders; duration of tinnitus); individual patient characteristics (e.g. age, gender, race, personality, lifestyle, acoustic environment, medical or mental health comorbidities, hyperacusis, third party coverage) and symptom characteristics (e.g. origin of tinnitus, ototoxicity, duration of tinnitus, etiology of tinnitus, severity of tinnitus) (KQ3) may result in outcomes such as changes in sleep disturbances, reduction in discomfort, anxiety, or depression or increased quality of life. Also, adverse effects, such as worsening of tinnitus, may occur at any point during or after the treatment is received.