# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- David M. Baguley, B.Sc., M.Sc., M.B.A., Ph.D.
  Head of Service, Audiology/Hearing Implants
  Cambridge University Hospitals
  Cambridge, Cambridgeshire, United Kingdom
- Carol A. Bauer, M.D.
  Professor of Surgery
  Division of Otolaryngology - Head and Neck Surgery
  Southern Illinois University School of Medicine,
  Springfield, IL
- Michael Borenstein, Ph.D.
  Director, Biostat Inc.
  Englewood, NJ
- Adrian Davis, O.B.E., FFPH, FSS, FRSA
  Professor, Director of the NHS
  London, United Kingdom
- Hugo Hesser, M.Sc., Ph.D.
  Lecturer and Researcher
  Department of Behavioural Sciences and Learning
  Linköping University
  Linköping, Sweden
- Glynnis Tidball, B.A., D.L.I.N., M.Sc., RAUD
  Audiologist
  St. Paul’s Hospital Tinnitus Clinic, Providence Healthcare,
  Vancouver, British Columbia, Canada