# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Gerhard Andersson, Ph.D.
  Professor, Department of Behavioural Sciences and Learning
  Linköping University
  Linköping, Sweden
- Brian Blakley, M.D., Ph.D., FRCSC
  Professor, Director of Research
  Department of Otolaryngology
  University of Manitoba
  Winnipeg, Manitoba, Canada
- James A. Henry, Ph.D.
  Research Career Scientist
  National Center for Rehabilitative Auditory Research
  VA Medical Center
  Research Professor in Otolaryngology/Head and Neck Surgery
  Oregon Health & Science University
  Portland, OR
- Don McFerran, M.A., FRCS
  ENT Surgeon, Colchester Hospital University NHS Foundation Trust
  Previous Chair, Professional Advisers’ Committee of the British Tinnitus Association
  Colchester, Essex, United Kingdom
- Larry E. Roberts, Ph.D.
  Professor Emeritus
  Department of Psychology, Neuroscience, and Behaviour
  McMaster University
  Hamilton, Ontario, Canada
- Robert W. Sweetow, Ph.D.
  Professor of Otolaryngology
  University of California, San Francisco, CA