# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Richard Birtwhistle, M.D., M.Sc., FCFP
  Family Practitioner
  College of Family Physicians of Canada
  Kingston, Ontario, Canada
- Daniel Born, B.A.
  Director of Research & Special Projects
  American Tinnitus Association and Experiences Tinnitus
  Portland, OR
- Jennifer Born, B.A.
  Director of Public Affairs and Coordinator of Action Alliance
  American Tinnitus Association
  Portland, OR
- Keith Folkert, M.D., M.H.A.
  Medical Director
  Blue Cross Blue Shield of Minnesota
  St. Paul, MN
- James A. Henry, Ph.D.
  Research Professor in Otolaryngology
  Oregon Hearing Research Center
  Portland, OR
- Kris Schulz, M.P.H.
  Chief Research Officer
  American Academy of Otolaryngology–Head and Neck Surgery
  Arlington, VA
- Glynnis Tidball, B.A., D.L.I.N., M.Sc., RAUD
  Audiologist
  St. Paul’s Hospital Tinnitus Clinic, Providence Healthcare
  Vancouver, British Columbia, Canada