# Acknowledgments

The researchers at the Evidence-based Practice Center (EPC) would like to acknowledge the following people for their contributions.

We are grateful to our Task Order Officers at the Agency for Healthcare Research and Quality, Supriya Janakiraman and Chuck Shih, for their support and guidance throughout the development of this report. Members of the Technical Expert Panel were instrumental in the formation of the parameters and goals of this review. They are listed below.

We would also like to thank those who worked so conscientiously retrieving and screening citations, abstracting data, preparing figures, and editing the report: Julianna Beckett, Judy Brown, Amy Bustamam, Patricia Carson, Bryan Cheeseman, Roxanne Cheeseman, Louise Don-Wauchope, Angela Eady, Mary Gauld, Suzanne Johansen, Sara Kaffashian, Meghan Kenny, Leah Macdonald, Maureen Rice, Carrie Sniderman, Rob Stevens, Marroon Thabane, and Ian White. Our thanks to Harry Shannon and Nancy Santesso for providing statistical assistance along the way.

Thank you to our Peer Reviewers for the thoughtful comments.