# Discussion

## Overview

In a rehabilitative context, those with tinnitus are more likely than those without tinnitus to seek professional help and accept hearing aids, presumably because the combination of tinnitus and hearing loss increases disability.4,65 However, for the large number of people with hearing loss and tinnitus, typical audiological interventions focus on the remediation of hearing loss rather than on treatments for tinnitus per se.4 Tinnitus is a complex condition for which a variety of interventions have been applied. This Comparative Effectiveness Review (CER) attempted to evaluate Key Questions (KQ) 1 and 3 regarding methods to assess different treatment strategies, and possible prognostic factors, related to tinnitus outcomes. Although the search was comprehensive, there was no literature eligible for KQ1 and KQ3, thereby identifying some significant gaps in the literature. For KQ2, which examined treatments for tinnitus, this CER has identified and shown that the strength of evidence (SOE) is generally of low quality, suggesting that the results of these studies do not necessarily reflect the true effect of these interventions and that future research is very likely to change both the direction and magnitude of the effects for these interventions. This evidence review demonstrates the research gaps with respect to KQ1 (methods to identify further evaluation and treatment) and KQ3 (prognostic factors).

A critical discussion for each of the KQ is presented below.

### KQ1 In patients with symptoms of tinnitus (e.g., ringing in the ears, whoosing sounds) what is the comparative effectiveness of methods used to identify patients for further evaluation or treatment?

The intention of this question was to determine if some methods were more effective than other methods when used by primary care providers or specialists in tinnitus care to determine if a patient with tinnitus should be referred for rehabilitation. Note that the type of tinnitus was not restricted for KQ1. The criteria for including studies allowed methods that involved direct observation or observation of sound with a stethoscope, the administration of scales/questionnaires to assess severity. Importantly, these studies were restricted to primary and specialty care with the specific outcomes of the method establishing any of the following: 1) no treatment necessary; 2) need for specialized treatment; and, 3) extent of intervention. This last criterion was the one that most affected eligibility for this systematic review.

There are several validated questionnaires23 currently being used for assessing the symptoms and the impact of tinnitus and very recently a new comprehensive instrument, the Tinnitus Functional Index (TFI),26 was developed by consensus among a large number of researchers who had introduced earlier measures. Nevertheless, no research has contrasted one measure with another existing instrument in order to evaluate which was better for addressing candidacy for further treatment or the type and amount of treatment required. Similarly, psychological grading scales, which can help discriminate between clinically significant and non-significant degrees of tinnitus, were not compared directly. Furthermore, the relative suitability of different methods for evaluating candidacy for and likely outcomes of specific treatments has not been studied. Some attributes regarding the potential usefulness of different measures and the criteria for treatment candidacy are suggested in the studies examined in regard to KQ2. Future research in this area is critical in order for the field to move forward.

It is noteworthy that, in parallel with the evolution of behavioral interventions, tinnitus-specific measurement tools have evolved to incorporate more of the psychological aspects of stress/distress with reduced focus on auditory perception. This reflects the historical development and understanding that tinnitus as a symptom is to be managed rather than a disease to be cured. It also highlights the potential problem of comparing studies using different instruments to establish either the candidacy for or the efficacy of treatments when the instruments are based on vastly different assumptions about the nature of the problems associated with tinnitus. Future evidence syntheses will have to judiciously consider the various domains within complex instruments encompassing multiple areas of quality of life or symptoms. Specifically, many of the tinnitus-specific measures (Table 5) include questions concerning multiple outcomes of interest in the present review. It is noteworthy that this dilemma is not unique to the area of tinnitus; efforts to bank individual items rather than summary scores when making outcome comparisons is endemic in rehabilitation areas where disorders are complex. Comparison of findings across studies when outcomes contain different domains and weightings of items within these domains has necessitated consensus work to establish core measures (a minimal set of functions or items) to capture important domains based on the International Classification of Function (ICF) (see example for stroke148). Note that an ICF core set for hearing has almost been completed (http://www.icf-research-branch.org/icf-core-sets-projects/other-health-conditions/icf-core-set-for-hearing-loss.html). Ultimately, it would be useful to develop such a core set for tinnitus and the TFI promises to be an important step in this regard.

### KQ2 In adults with subjective idiopathic (nonpulsatile) tinnitus, what is the comparative effectiveness (and/or potential harms) of pharmacological, medical, sound treatment/technological, or psychological/behavioral interventions (including combinations of interventions)?

In general, it is difficult to draw overall conclusions about treatment benefits given the diversity of interventions and outcomes in the studies that satisfied the inclusion criteria for this research question. Studies were heterogeneous in terms of populations, treatments, treatment modalities (e.g., many different types of CBT), study duration and followup periods, and outcome measures. Although we estimated effect sizes using standardized mean differences, they are difficult to interpret. Some interventions did show positive benefits, but it was difficult to judge the degree of clinical significance of the changes across studies. Even if differences in treatment-placebo scale scores were statistically significant, these differences may not be clinically meaningful. Future research must consider pilot work to establish the validity of many of the outcomes used in the studies eligible for this question; moreover, specific adaptations of measures validated in non-tinnitus populations (i.e., study-specific visual analogue scales (VAS) should be established in the tinnitus population, particularly for the attributes of change over time (responsiveness). For some of the tinnitus-specific outcomes, it is critical that clinically important differences be established.

For some interventions (e.g., pharmacological agents, acupuncture, Qigong, etc.), only single studies were evaluated and many of these were very small with respect to sample sizes. One clear trend was that, given their sample sizes, many studies were likely underpowered to detect differences. Thus, there is little or no confidence in the findings of studies that showed no differences relative to placebo or inactive control comparators, and it is prudent to assume that these do not reflect the true effect of the interventions being evaluated.

Perhaps the heterogeneity among studies reflects differing paradigms based on evolving knowledge about the nature of tinnitus. It would be important that future studies designed to evaluate interventions be well grounded in neuroscience and reflect a conceptual framework providing rationales that take into account the auditory, cognitive, emotional, and stress circuits thought to underpin the characteristics of the disorder. It may also turn out that different subtypes of tinnitus will be identified according to whether the main feature of the tinnitus relates to auditory, cognitive, emotional, or other disorders. Recent research findings from cognitive and auditory neuroscience studies have advanced knowledge of the biological mechanisms for some forms of tinnitus, while findings from clinical psychology studies have underscored the interactions among the auditory, cognitive, affective, and mental health issues that must be considered when designing and evaluating interventions to meet the needs of clinical subpopulations of patients.

The perspective brought to this evidence synthesis is that tinnitus is a symptom or condition and not a disease, suggesting that it is multi-factorial and complex. As such, it is not surprising that the focus of interventions is shifting from “curing” tinnitus by trying to mask or eliminate the perception of tinnitus to providing strategies for coping/control/relief. The auditory aspect of tinnitus was an early focus of many of the treatment approaches to manage it, with many of those suffering from tinnitus seeking medical rather than psychological treatments; in contrast, the present understanding of the problem would suggest that the “sound” per se is not the only issue.18 Rather, the reaction to the sound suggests that it is more than just an auditory problem; tinnitus often entails psychological distress.12 Nevertheless, new sound generating technologies continue to be developed and tested.116 The implications of this for future research are to continue to broaden baseline assessments and types of outcomes to capture these additional dimensions. A systems approach that addresses the interaction of the auditory, emotional, and cognitive aspects of tinnitus could be considered.

The diversity of interventions and treatments eligible in this review did not provide guidance with respect to the dose of the treatment interventions (for how long and how much) to achieve an acceptable effect. The studies evaluating CBT provide some information about the amount of clinician-patient contact required to achieve statistically significant outcomes; the primary motivation being to design programs that can be self-administered or delivered over the phone or internet in order to improve cost/benefit, accessibility, varying needs of patients, and efficiencies in the allocation of limited clinician resources. Future studies may need to consider earlier phase trial designs to establish adequate doses for the various interventions. Contextual parameters also need to be considered with respect to the setting and the personnel providing the service and what type of specialization is required for the specific intervention.

This review considered adverse effects related to tinnitus symptoms (worsening of tinnitus, sedation symptoms, and surgical complications). From these, the SOE for sedation (drowsiness, excessive sleepiness) could be evaluated and this effect was reported in studies evaluating primarily pharmacological interventions. The evidence was rated as insufficient for the outcome of sedation, due to the diversity of drugs and the few studies that reported this adverse effect. Some of the studies evaluating other pharmacological and medical interventions also attempted to capture and report other types of treatment emergent adverse effects. However, almost none of the psychological behavioral interventions evaluated or reported adverse effects and those that did indicated that there were no adverse effects. In some studies, worsening of tinnitus-related symptoms was noted.92 Although, it may be difficult to identify potential unintended effects with these types of psychological and behavioral therapies, it would still be important to consider what some of these might entail. Whereas patients who see no effect with a medical/surgical intervention, such as a drug, may tend to feel that the medication failed them and not that they failed the medication. In contrast, participants in psychological/behavioral interventions may tend to feel that they failed the psychotherapies. For example, the patient who commits to psychological therapy and then experiences no improvement might tend to be emotionally troubled by this result (if they had tried harder, been more open, done the homework, participated in group more, etc.). In general, it was observed that the majority of studies evaluating these interventions did not adequately identify or collect potential adverse effects. The inability to distinguish whether the studies measured these harms as opposed to simply not reporting them, either because no events occurred or they occurred at the lowest frequencies, makes rating SOE for outcomes of harm problematic.

Future research should adequately capture harms, particularly if head-to-head trials comparing two different treatments are of interest. That is, if there is no meaningful difference in the potential outcomes of benefit, the margins between benefits and harms become narrower. Given that many of the treatments evaluated were likely to have no difference or are potentially equivalent, evaluation of harms takes on a greater importance for judging the relative efficacy of the two interventions.

Trial registries were reviewed to ascertain what future trials are ongoing (Appendix F) and 26 registered trials were found. The largest number of trials are evaluating sound technologies interventions using varied sensory stimulation devices (n=6); additionally, four trials will be evaluating repetitive transcranial magnetic stimulation (rTMS), and two assessing vagal nerve stimulation. Five trials are registered to evaluate pharmacological agents (i.e., cilostazol, NST-001, AM-101, and neramexane mesylate) or food supplements (i.e., magnesium). One trial will compare the efficacy of a behavioral intervention to a pharmacological agent. There are seven trials registered that will evaluate psychological/behavioral interventions. Overall, this reflects significant research activity in interventions aimed at remediating problems associated with subjective idiopathic tinnitus using a wide range of interventions.

### Studies Involving Pharmacological and Food Supplement Interventions

A total of 16 unique studies28,82,85,86,90,93,106,107,109,111,113–115,117,119,122 evaluated the efficacy of pharmacological interventions or food supplements in tinnitus. The studies examined six outcomes: TSQoL, subjective loudness, sleep disturbance, anxiety symptoms, depression symptoms, and global QoL. Another article99 contained additional data to supplement one of the study publications.122

The included studies evaluated 14 different interventions, all but one of which were compared to some form of placebo. In a crossover study,107 all participants received Deanxit in addition to clonazepam, with the comparator being placebo in addition to clonazepam. The study of honeybee larvae85 involved hydrogenated dextrin as the comparator. Authors of the included studies measured outcomes using a multitude of different instruments, ranging from validated scales such as the HAM-D to 10-point or 100-point VAS. For the most part, the interventions failed to demonstrate statistically significant effects compared with placebo on any of the six outcomes. Various interventions did show statistically significant effects on some outcomes: nortriptyline115 and honeybee larvae85 for depression; alprazolam28 and zinc86 for loudness; and acamprosate82 for TSQoL measured as ‘disturbance’. One study115 found conflicting results for tinnitus-specific QoL depending on the outcome measure.

The only intervention that consistently showed statistically significant effects on multiple outcomes was sertraline, which was evaluated against placebo in a 16-week study of 63 persons who had a mean age of 42 years. These persons were recruited from a specialized audiology clinic and given 50 mg/day of the active therapy or placebo. Sertraline was shown to be more efficacious than placebo in reducing loudness, improving global QoL, and alleviating severity. Sertraline also had a greater impact on reducing depression symptoms, although the reduction failed to reach statistical significance at the 5 percent level on one of the three scales used to measure depression.

Several issues must be considered when interpreting the results described above. Although sertraline does appear to have beneficial effects on certain tinnitus outcomes, this medication has only been evaluated in one 2006 study.122 More evidence is required prior to drawing firmer conclusions about the drug’s usefulness against tinnitus. The same caution is relevant for the other therapies that did not show any benefits against tinnitus. Further research is required for us to assess whether or not these treatments are beneficial for persons with tinnitus.

Thirteen of the 16 studies had sample sizes of less than 100 persons. Most of these papers were bereft of sample size calculations or author commentaries on the adequacy of their sample sizes. This issue raises the question of whether the studies had adequate power to detect statistically significant differences, let alone minimum clinically meaningful differences. Although the three largest studies93,109,113 did not find differences between the treatment and placebo groups, these results cannot be used to conclude that the smaller studies would also not have found differences had they employed larger samples. Each of the three large studies evaluated a different active therapy and, in only a single case did a smaller study examine one of the same therapies as in a larger study.93,111 Thus, the results of the larger studies are therapy-specific and in no way generalizable to the findings for the other treatments.

The issue of minimum clinically meaningful differences is important when one considers the characteristics of the outcome measurement instruments used in the included studies. Few of the authors commented on the validity of their instruments, both in terms of measuring the outcomes of interest or for assessing these outcomes specifically in persons with tinnitus. Even though some instruments might be suitable measures of tinnitus-specific outcomes (e.g., Tinnitus Handicap Inventory for symptom severity), and other instruments might be valid measures of constructs such as depression (e.g., HAM-D), the authors did not provide details on the minimum changes in instrument scores that would be considered clinically meaningful. For example, the sertraline study122 used a 100 mm VAS to measure loudness and the authors reported that the mean change in score between baseline and the end of 16 weeks of followup was 15.21 (standard deviation=20.38) in the treated group and 3.21 (standard deviation=20.91) in the placebo group. For clinicians or persons with tinnitus, does a mean score change of 15.21 indicate that a majority of patients on the active treatment were clinically improved? Also, is the treatment-placebo difference in mean score change at the end of followup (i.e., 12.00) indicative of an important clinical difference between the study groups? The same questions apply to all of the instruments used in the included studies (AS and validated instruments alike. It is recommended that authors justify their choice of outcome measures from the standpoint of validity. Additionally, authors should specify (and justify) the minimum differences in instrument scores that are claimed to be clinically important.

Another important issue to consider is the ability of an instrument to discriminate between treatment effects across study groups (in other words, the ability to detect minimum clinically meaningful differences). Even valid instruments might contain a certain degree of imprecision that blurs between-group differences. In some cases, the imprecision might be large enough to prevent researchers from detecting true effects. In other cases, the presentation of summary scale scores might obfuscate the imprecision and make the differences between treatments appear larger than in reality. To see an illustration of the latter point, the standard deviations associated with the mean VAS scores in the previous paragraph exceed the mean scores themselves. Assuming the data are normally distributed, a standard deviation of 20.38 for the sertraline group means that 34.1 percent of the 29 persons who received this drug (n~10) actually had a change in score of somewhere between −5.17 (worsening loudness) and 15.21 on the VAS (mean – standard deviation). Also, 15.8 percent (n~4 – 5) had a change in score that was worse than −5.17. For the placebo group, 34.1 percent of the 34 persons who received placebo (n~11 – 12) had changes in score between 3.21 and 24.12 (mean + standard deviation). A further 15.8 percent of the placebo group (n~5) had changes in score that exceeded 24.12. When considered in this fashion, the differences between the active and placebo groups do not appear as great as the means suggest. Authors must carefully consider an discriminative ability of an instrument prior to use in a study. Such consideration will mitigate the potential of a type II error (failing to reject the null hypothesis when it should be rejected) or prevent treatment differences from appearing larger than in reality.

### Studies Involving Medical Interventions

Eleven studies evaluated four different types of medical interventions that included rTMS,83,88,103,105,110 electromagnetic stimulation,94 low level laser therapy (LLLT),35,89,108 acoustic coordinated reset neuromodulation (ACRN),116 and acupuncture.118 Almost all studies in this grouping evaluated tinnitus-specific QoL. In general, the SOE for TSQoL is rated as low or insufficient based on the high risk of bias, and the small sample sizes, lack of power calculations, and lack of specification of the primary outcomes are factors related to the imprecise rating. Many of the studies did not show statistical differences between groups, but limited statistical power is likely an important factor.

When considering the individual types of interventions and efficacy with respect to TSQoL, the studies consistently showed no significant difference between treatment and inactive comparators. For rTMS and electromagnetic stimulation the evidence was rated as insufficient. There was some evidence that longer term effects (improvement in TSQoL scores) occurred with low frequency rTMS (1 Hz) up to 6 months followup83 but this single study was at high risk of bias. This review also showed that adverse effects were generally poorly evaluated and reported. A previous systematic review149 reached similar conclusions suggesting that the evidence of benefit for rTMS is limited; also noted is the lack of long-term monitoring within the studies with respect to safety. Strength of evidence was rated as insufficient for TSQoL with respect to the interventions of ACRN, LLLT, and acupuncture.

When considering the outcome of perceived loudness, there were only five trials that evaluated this outcome35,88,108,116,118 and most trials showed no statistical differences between treatment and inactive control groups; however, the studies had small sample sizes and are at high risk of bias. A single study evaluating LLLT relative to sham LLLT evaluated an outcome capturing anxiety symptoms and depression symptoms;108 this trial was judged to have insufficient SOE. No studies evaluated the effect on sleep disturbance and global QoL with these interventions.

The studies in the medical intervention grouping have relatively small sample sizes (less than 60 subjects total) and none of the studies undertook formal power calculations. As such, type II error cannot be ruled out. Issues related to statistical power, poor characterization of study participants, and poor study conduct (high risk of bias) all likely contributed to the nonsignificant results observed across the different interventions. Future research should provide a more coherent rationale for the particular treatment approaches based on current neurological science principles, including justification for the dose of the intervention.

### Studies Involving Sound Technologies

The idea that external sound can cover up the internally generated sound of tinnitus or that external sound can provide relief or can distract a person’s attention away from tinnitus has led to the use of maskers or sound generators for tinnitus. The use of masking became popular over 30 years ago and it has long been observed that people with hearing loss and tinnitus often report relief from tinnitus when hearing aids are worn to amplify external sounds. Nevertheless, only four unique studies53,61,92,98 and a related study91 were eligible for inclusion in this review, all published within the last 15 years. It seems likely that research concerning the effectiveness of early forms of sound technologies predated the use of RCT methodologies. Another possibility is that research to investigate the effectiveness of sound technologies such as hearing aids and cochlear implants in populations with hearing loss, may have included measures of tinnitus relief, but the primary purpose of the research was to investigate benefits in terms of hearing rather than tinnitus outcomes.

It is noteworthy that all of the papers reviewed for this category of intervention were head-to-head trials, possibly also reflecting the relative maturity of sound-based interventions in audiology. Of the studies examined in the present CER, the emphasis was on whether or not the use of noise generators enhanced benefit from psychological/behavioral interventions such as CBT or tinnitus education,98 whether using one or another type of sound technology (sound generators vs. open ear hearing aids) for people with mild hearing loss had differential effects on benefit from tinnitus retraining therapy (TRT) counseling,61 whether benefit from an information intervention was augmented by the addition of a white-noise generator and/or relaxation,92 and whether or not benefit depended on the type of stimulation used in Neuromonics Tinnitus Training.53 Benefits from treatment were reported in some studies; specifically, benefit from treatment was reported for TSQoL based on THI scores, subjective tinnitus loudness and global QoL for the TRT interventions with either sound generators or open ear hearing aids61 and benefit from TSQoL based on TRQ scores was reported for the Neuromonics Tinnitus Training with either type of stimulation.53 However, no study reported any significant difference between the treatments evaluated on any outcome measure.

Similar to the issues raised above for the other interventions, the SOE is limited by relatively small sample sizes of less than 100 per group. In two studies,92,98 pre-/post-treatment comparisons were analyzed to establish any benefits from intervention. In all cases the varieties of treatment evaluated were primarily focused on determining whether one or more treatment components enhanced another and the characteristics of the subpopulations tested were usually well defined (e.g., only people with mild hearing loss61). The comparison of treatment measurement issues are similar and perhaps even more challenging when compared to the issues raised previously regarding the test properties and clinical interpretation of test results when outcomes are measured to evaluate treatments versus an inactive comparator. In general, if the test properties and clinical interpretation of results were refined, then more research is to be encouraged to determine the specific contributions of treatment components for tightly controlled subpopulations. Two recent systematic reviews evaluating a different set of eligible studies derived a similar conclusion suggesting insufficient evidence7 or remarked upon the diversity of interventions and the lack of evidence overall.150

### Studies Involving Psychological/Behavioral Interventions

Similar to the medical interventions, the psychological and behavioral interventions were diverse and a clear overall summary of effects was difficult to ascertain. Even the studies that had similar interventions had marked differences in the focus and administration of the therapy, rendering between-study comparisons problematic. Despite this diversity, this review judged the SOE to be of low strength for CBT and coping approaches, suggesting low level of confidence that the studies evaluating these interventions reflect the true effect for outcomes of importance analyzed (i.e., evidence of benefit for TSQoL and no effect for other outcomes). Two independent systematic reviews and meta-analyses55,58 evaluating CBT-based interventions only and with slightly different set of included studies relative to this review, have a beneficial effect on TSQoL measures as compared with active controls. One review55 also confirmed these findings with respect to subjective loudness; however differences with respect to CBT therapies positively affecting depression symptoms were determined. Note that the apparent absence of benefits from treatment for outcomes related to anxiety and depression symptoms may not be meaningful given that most of the participants in the studies had no more than mild symptoms pre-treatment. Recent systematic reviews have evaluated TSQoL and CBT interventions and rated the evidence as moderate7 or showed evidence of benefit.7,55,58,150 This systematic review did not undertake comparisons between studies with inactive and active comparators. Other systematic reviews that have addressed this issue suggest that there is no difference with respect to the comparator group and the efficacy of CBT interventions on TSQoL. One review55 included eight studies and three of these had yoga or education as the comparator groups; the other five studies were wait list control. There were no specific conclusions about active versus inactive controls, but for the outcome of quality of life (equivalent to TSQoL in this report) they conclude that the studies with wait list control showed a larger effect size. A second review58 performed a subgroup analysis comparing studies with active and inactive controls and only found a trend that analyses of active control conditions (education controls or credible treatment controls) had significantly lower effect sizes than analyses with passive control groups (wait list control). However, CBT compared with a passive and active control at post assessment yielded statistically significant mean effect sizes for tinnitus-specific measures (Hedges’s g=0.70, and Hedges’s g=0.44, respectively) based on post treatment means only; this suggests that CBT was effective in both active and inactive comparator studies. Another150 evaluated 10 RCTs that compared CBT to a non-CBT control, of which nine reported significant improvements in tinnitus intrusiveness. Their findings indicate that this positive effect appears to be independent of whether CBT is compared to an educational or wait list control, suggesting that either measure adequately controls for placebo effects in these studies. Although there were fewer studies using active controls, comparisons in these three other systematic reviews would suggest that the comparator does not affect the main conclusion that CBT interventions appear to improve quality of life relative to both active and inactive controls. One of these previous reviews also suggests that the evidence shows that CBT interventions do not affect depression and anxiety symptoms,150 and other reviews suggests the evidence demonstrates that CBT improves depression scores55 or mood.58 One review showed no evidence of CBT affecting subjective loudness.55

Behavioral interventions (i.e., relaxation, education, TRT) employed an isolated approach that did not confer the same degree of benefit and were rated insufficient, being plagued with the same problems as the studies evaluating pharmacological and medical interventions. It was observed that CBT combined with other behavioral interventions (e.g., EMG biofeedback18 in this review) were common treatment options. There has also been a movement attempt to tease apart the active ingredient of some complex interventions or to compare treatments with demonstrated benefit to each other. Two recently published RCTs151,152 that were not indexed at the time the databases were searched for this CER illustrate this point. The first report151 showed that both internet CBT and internet ACT yielded equivalent benefit with the conclusion that either are viable treatment alternatives that may be chosen by or for patients. It is interesting that there is active development of progressive46,63 or staged treatments,64 which could be a promising avenue to further explore in future studies. The second report152 is an example of a staged treatment study in which benefits on a new measure of tinnitus-specific quality of life were found. The group receiving a psychoeducational intervention, followed by 6 weekly sessions of mindfulness training that emphasized acceptance, showed benefit but the same psychoeducational intervention followed by a relaxation therapy did not. However, trials evaluating complex interventions are problematic if a simple parallel design is employed. Factorial designs will assist in disentangling the relative benefits of the different components of multi-modal interventions.151,152

### KQ3 For adults with subjective idiopathic symptoms of tinnitus, what prognostic factors, patient characteristics, and/or symptom characteristics affect final treatment outcomes?

The intent had been to identify from the literature important patient characteristics, symptom characteristics and/or prognostic factors that might affect final treatment outcomes. This systematic review did not identify any literature relevant to addressing this Key Question that met inclusion criteria. Although most studies identified baseline population characteristics, between group analyses of treatment effect were only presented for the main treatment and control groups and not for subgroups differing in the characteristics targeted by KQ3. Furthermore, relationships between patient characteristics and outcomes were not tested (e.g., multivariate regression models evaluating independent contributions of different factors to predict the outcomes of interest). For the included studies, when subgroup results were presented, the focus was not on predicting the effect on prognosis, rather the analysis was more descriptive rather than predictive. This identifies another important gap in the literature. In part this can be related to the evolving issues of diagnosing or establishing the severity of tinnitus, as well as the changing paradigm from the neuroscience perspective.

## Applicability

When considering the applicability of study findings in general, the study populations were relatively homogeneous and were limited to mostly middle aged (≥50 years of age) persons suffering from predominantly subjective idiopathic tinnitus of mild to moderate severity. Of course, age-related hearing loss also increases markedly with age starting in the fourth decade and hearing loss and tinnitus often co-occur.4 Nevertheless, tinnitus is not only a problem for older adults or for people with clinically significant hearing loss. A recent survey estimated tinnitus was prevalent in 12.2 percent of the U.S. population under 44 years of age.113,153 However, there is little evidence upon which to draw conclusions about the efficacy of the therapies in persons younger than 42 years of age. Some studies did focus on industrial workers81 or veterans,97 but these specialized populations may differ from the general population of working-aged people because of the relevance of the link between tinnitus and their occupational exposure to noise and trauma. Importantly, it seems that there may be generational differences in the experience of tinnitus based on recent epidemiological research on adults over the age of 45 years.154 The finding of generational differences suggests that reports of tinnitus tend to increase with more recent birth cohorts compared with earlier birth cohorts,154 with participants in a given generation being significantly more likely to report tinnitus than participants from a generation 20 years earlier (OR=1.78; 95% CI, 1.44 to 2.21). Such cohort differences could extend to younger adults, especially given recent concerns about a rise in tinnitus related to exposure to recreational noise.6 The generational differences in the reporting of tinnitus may reflect actual changes in prevalence related to lifestyle and environmental differences across cohorts. They may also reflect changes in health attitudes or knowledge that awareness of, and willingness to report, the symptoms. In any case, it is possible that the effectiveness of treatments may differ with age or cohort and it will be important to explore these differences as programs to treat, and possibly even programs to prevent, tinnitus continue to be developed and evaluated.

Tinnitus is a chronic condition and the longest followups in the included studies did not exceed 16 weeks in pharmacological and food supplement studies and 26 weeks in medical interventions. However, followup was extended to 12 months in all of the studies evaluating sound-based treatments53,61,92 and even to 18 months for one study.98 For the psychological and behavioral interventions, many studies evaluated the effectiveness of treatment immediately post-treatment as well as at one or more later followups. The time intervals ranged from a minimum of 6 weeks10 to 2 months,62 or 3 months84,87,102 to 6 months,96 but most continued to 1 year17,57,95,97,100,104 or even 18 months.120 Thus, for the pharmacological and medical intervention categories of intervention, the included studies did not provide data on the medium- to long-term effects of the active treatments. Longer term followup was provided in the studies involving sound-based therapy and psychological/behavioral therapies. These therapies are usually provided by rehabilitative professionals, such as audiologists and psychologists whose practice may put greater emphasis on establishing and maintaining change due to intervention.

Most studies were recruited from clinical or specialty settings. Fewer studies recruited subjects from newspapers and the Internet (open to the public, including associations for tinnitus/hearing loss), which is reflective of the population most likely to benefit from the interventions. However, this method of recruitment might account for the high attrition rates in these studies. Also, for some studies, the subjects represented those who had failed to respond to previous treatments; although the subjects were seen in otolaryngology clinics, they were treated by psychologists, often in conjunction with audiologists. It is not clear what proportion of all tinnitus patients fall into this “failed treatment group”. Two of the studies with failed populations focused on high risk groups. While one of these studies suggests that group educational counseling can be of significant benefit to many tinnitus patients,97 the focus on subjects who are veterans may limit the applicability to the general population. This is also an issue for the study that focused only on those 65 years of age and older.84

As noted previously, it is difficult to judge the applicability of the doses for the varied interventions in the included studies. The pharmacological and food supplements, sound technologies, and medical interventions would be readily available in primary care, rehabilitation, and audiology settings. Some of the psychological interventions might be more problematic to implement across different healthcare systems.

Many of the studies in this review were conducted in Europe, where the professional model of ‘hearing care/audiology’ is different from that typically seen within the United States. In the United States, the coping/CBT-oriented interventions fall more within the scope of the practice of psychologists, rather than audiologists. If future interventions were to require more of this type of psychological intervention, there would need to be a shift in the training of audiologists or a shift to more team-oriented practice involving both audiologists and psychologists. Added to this, interventions delivered via the Internet are now in use.57 Translating all of this into practice has some implications for the education of various health professionals and for the cost/benefit of these newer treatment delivery methods.

## Comparative Effectiveness Review Limitations

This CER has several methodological limitations related to the literature search. Although over 9,700 citations were screened, these were limited to ones published in the English language. The studies were restricted to randomized parallel group trials. Crossover trials were reviewed but none had first period data and as such were excluded. Given the diverse interventions, different treatment intervals, and varied followup times, only data across interventions based on the end of treatment and longest followup time was presented. This makes comparison across studies and interventions challenging.

Conflict of interest may be of concern when devices or proprietary interventions are used. A review of the relevant studies revealed that most did not disclose this potential conflict of interest. However, when we were aware of potential conflict of interest, it was noted within the presentation of the results.

There were 22 studies that were eligible for the review but they did not provide measures of variance to allow estimation of an effect size, or provided information in proportions of individuals who changed following treatment and, as such, did not provide baseline measures.

A search of the grey literature was undertaken to identify unpublished trials; however, this avenue did not provide any additional literature. We did not formally assess publication bias as these computations are known to be inaccurate. Based on previous literature that suggests that studies with small sample sizes are at greater risk of publication bias, it was assumed that these groupings of studies were at risk.79 Some manufacturers were contacted and scientific industry packages (SIP) for tinnitus-related devices from the MED-EL Corporation (manufacturers of several models of cochlear implants) were received. Although unpublished information was provided regarding research done with their products, none met inclusion criteria. As well, noted by the contacting information officer, MED-EL cochlear implants are not FDA approved in the United States to treat tinnitus. Another information package was received from Neuronetics, manufacturers of the NeuroStar TMS Therapy System^®^. This company has not sponsored any clinical trials, published or unpublished, for their transcranial magnetic stimulation device, nor was this the device used in the TMS studies included in this review; the SIP did not provide any information that had not already been reviewed in the screening process or applied directly to the Key Questions.

A review of trial registries to identify ongoing trials would suggest that research in treatment for tinnitus is a very active area of research (n=26). This review did not identify any studies evaluating sound technologies relative to inactive controls; however, seven trials with such devices are ongoing. Completion of these trials will contribute to future knowledge about the relative importance of these types of interventions.

## Summary/Conclusions

### Key Question 1

No studies were found addressing the comparative effectiveness of tools used to determine candidacy for treatment. A gap in the literature has been identified.

### Key Question 2

#### Pharmacological and Food Supplement Interventions

We summarized the evidence contained in 16 RCTs that examined pharmacological interventions or food supplements for use in the treatment of tinnitus. The evidence related to six outcomes was examined: TSQoL, subjective loudness, sleep disturbance, anxiety symptoms, depression symptoms, and global QoL. Although some evidence was found to suggest that some therapies led to improvements over primarily placebo comparators on some outcomes, the results were inconsistent and many treatment differences were not statistically significant at p<0.05. The findings of this review agree with the conclusions of previous systematic reviews, which found insufficient, inconsistent, or no evidence of treatment effects.7,150,155–158

In terms of SOE, there is primarily insufficient information to assess whether the published evidence reflects true effects. Effect size estimates were inconsistent or imprecise, and risk of bias was medium. Furthermore, most treatments were evaluated in single studies, which may or may not represent the true effect of any particular therapy. Sample sizes tended to be small (< 100 persons) and power calculations were largely absent from the published reports, leading to the possibility that many studies were underpowered to detect true effects. Lengths of followup were too short to assess the durability of treatment over time and the validity and discriminative ability of many outcome measurement instruments was questionable.

#### Medical Interventions

Four different medical interventions were evaluated in 11 randomized trials. There was low SOE for rTMS and insufficient evidence for LLLT, ACRN, and acupuncture for improving TSQoL. The studies were generally at high risk of bias, with small sample sizes and were poorly reported. Few studies evaluated subjective loudness, anxiety symptoms, and depression symptoms. There were insufficient studies to evaluate the evidence. No studies evaluating medical interventions assessed the impact on sleep disturbance or global QoL. A clear trend for harms was difficult to specify across the differing interventions. The relative potential for long-term harms was not evaluable in the short term treatment trials included in this grouping.

#### Sound Technologies Interventions

Four unique RCT, all head-to-head comparisons, evaluated the relative effectiveness of variants of sound-based intervention to determine whether or not benefits, primarily in terms of tinnitus-specific and global QoL and loudness, were enhanced when sound generators were combined with CBT, information, or relaxation or to determine if different versions of sound generators resulted in different outcomes. Half of the studies reported some benefits from treatment, but none demonstrated any significant difference between the treatments that were compared. Similar shortcomings to those discussed for the other interventions also apply to this category of intervention.

#### Psychological and Behavioral Interventions

Four subcategories of psychological/behavioral interventions were examined: CBT (n=10) and related treatments, TRT-related treatments (n=2), treatments involving primarily relaxation (n=3), and other interventions (n=5), including one involving reading tinnitus books, two emphasizing education, one with yoga, and one with Qigong. Outcomes for TSQoL (19 treatments), subjective loudness (13 treatments), sleep (6 treatments), anxiety (9 treatments), depression symptoms (17 treatments), and global QoL (8 treatments) were measured using a large variety of measures. The SOE for psychological/behavioral interventions was rated as low for the outcome of anxiety symptoms. Low SOE indicates that future research will likely change the magnitude and possibly the direction of the observed effects. Interventions involving CBT were deemed to have low SOE for the outcomes of TSQoL, perceived loudness, anxiety, depression global QoL suggesting that the impact of future research will likely change the magnitude of the effect size to a lesser degree than the other interventions rated as low. Adverse effects were largely not reported in this intervention group. Some studies reported an absence of adverse effects, with the exception of one study where some patients reported that the self-monitoring of the loudness and discomfort caused by their tinnitus resulted in the worsening of those symptoms.

### Key Question 3

No studies were found identifying potential prognostic factors. A significant gap in the literature has been identified.

## Future Research Recommendations

Previous attempts have been made to identify issues related to the design and conduct of clinical trials evaluating interventions for patients with tinnitus.19,159,160 Future research should attempt to incorporate the following recommendations for primary studies evaluating patients with subjective idiopathic tinnitus.

### Population

1. Include a broader representation of adult patients with respect to age (range of middle age to old/elderly), gender (equal proportion of men), and ethnicity (increased proportion of non-white or non-Caucasian, or provide broader representation of ethnic groups)
2. Include patients recruited from primary care settings to incorporate a complete spectrum of participants who have tinnitus
3. Capture detailed information about the prior treatments and ensure that future studies do not sample only from subjects who “failed to respond” to previous treatments when receiving new treatments
4. More adequately specify patient medical and mental health histories (i.e., medical comorbidities and previous mental health issues)
5. Collect information on the use of other co-interventions, including psychiatric and complementary and alternative medicine therapies that have the potential to confound and contaminate study interventions

### Intervention

1. Establish a clear rationale for the dose used for off-label medications
2. Measure the concomitant use of co-interventions that have the potential to confound interventions (e.g., other pharmacological agents)
3. Specify the training and experience of the person(s) providing the interventions
4. Standards for reporting beam parameters when evaluating LLLT; this will assist in the accurate estimation of the total energy and dose used to administer this treatment.161

### Comparator and Study Design

1. Establish sufficient sample sizes to show clinically important differences between treatment groups. Justify the chosen minimum clinically important difference and provide clear justification for the sample size, including a sample size calculation
2. Establish a sufficient sample size to evaluate potentially important confounders such as age, gender, and baseline severity
3. There may be a need to return to Phase II trials to establish therapeutic doses and preliminary efficacy margins. The data from these studies could be used to establish the parameters for Phase III trials
4. Consider open trials to select possible responders and assess their characteristics before undertaking RCT.19
5. Length of followup should be long enough to study medium- to long-term outcomes given the chronicity of tinnitus)
6. The use of wait list controls need to be carefully considered. Previous analysis suggests over a 6 to 12 week period, subjects can improve from 3 to 8 percent.162 The population included within studies (age, duration of tinnitus) are important to consider.

### Outcomes

1. Aim to encompass three principle components of tinnitus, that include: a) auditory feature of tinnitus perception (intensity, location, masking and pitch), b) emotional features ( distress), and c) attentional features (awareness of tinnitus in daily life).159
2. Identify primary and secondary outcomes within the studies
3. Consider the inclusion of patient-reported outcomes using scales with established psychometric properties, including responsiveness, in the population with subjective idiopathic tinnitus
4. Assess the validity and responsiveness (change over time) of outcome measurement instruments (VAS) in persons with tinnitus prior to using these instruments to evaluate the efficacy of tinnitus interventions
5. Ensure back translation of outcome measurement instruments prior to use in languages other than the language of development.
6. Measure global quality-of-life to capture how persons value the risk-benefit trade-off between the efficacy and adverse effects profiles of treatments under evaluation
7. Conform to the Consolidated Standards of Reporting Trials (CONSORT)163 reporting standards for harms. As such, severe and serious events should be defined a priori and the use of standardized instruments or terminology for reporting harms should be adopted. Long-term followup may be required to capture harms adequately

### Other

1. Develop or improve theoretical models about tinnitus severity and how distress is maintained or exacerbated in these patients.
2. Promote clarity in research and facilitate critical appraisal of the literature, whether for the benefit of a clinician who is seeking practice guidance or a systematic reviewer who is synthesizing evidence, authors of RCT should follow the (CONSORT) Statement. This set of guidelines encourages explicit reporting of RCT features so that readers may understand a study’s design, conduct, and analysis
3. Continue to register study protocols in clinical trial registries to allow researchers to evaluate the potential for publication bias and selective outcome reporting. Authors should endeavor to regularly update the information reported within these registries.
4. Studies should be developed to evaluate the natural history and prognostic factors in persons with subjective idiopathic tinnitus