# List of Ongoing Clinical Trials Evaluating Interventions To Treat Idiopathic Tinnitus Registered in Clinicaltrials.gov

Table F1 Ongoing clinical trials evaluating medical surgical interventions

Med/Surg Intervention Category | Study Title (NCT number) | Intervention | Sponsor Completion date
Psychoactive (Neurotransmitter) drugs | A Study on the Effect of Cilostazol in Patients With Chronic Tinnitus (NCT01378650) | Drug: Cilostazol; Drug: Placebo | Asan Medical Center; Jong Woo Chung; Korea Otsuka Pharmaceutical Co., Ltd December 2011; this study is currently recruiting participants
Other drugs | Safety Study for NST-001 and the Neuroject Injection Set to Treat Tinnitus (NCT00957788) | Drug: NST-001 | NeuroSystec Corporation December 2011; this study is currently recruiting participants
Other drugs | Comparison of Single Versus Repeat Doses of AM-101 in the Treatment of Acute Inner Ear Tinnitus (NCT01270282) | Drug: AM-101 | Auris Medical, Inc. February 2013
Other | Investigating the Neurobiology of Tinnitus (NCT01294124) | No Intervention: Prospective study | Washington University School of Medicine; Department of Defense May 2014
Other | A Trial of Magnesium Dependent Tinnitus (NCT01273883) | Dietary Supplement: Magnesium; Other: Placebo | Mayo Clinic July 2013

Abbreviations: med/surg = medical/surgical; NCT = National Clinical Trial

Table F2 Ongoing clinical trials evaluating medical surgical interventions using rTMS or vagal nerve stimulation

Med/Surg Intervention Category | Study Title (NCT number) | Intervention | Sponsor Completion date
Device: Repetitive Transcranial Magnetic Stimulation (rTMS) - ACTIVE; Device: Repetitive Transcranial Magnetic Stimulation (rTMS) - SHAM | Effect of rTMS on Resting State Brain Activity in Tinnitus (NCT00926237) | Device: Repetitive Transcranial Magnetic Stimulation (rTMS) - ACTIVE; Device: Repetitive Transcranial Magnetic Stimulation (rTMS) - SHAM | University of Arkansas; National Institutes of Health (NIH) March 2016
Device: repetitive transcranial magnetic stimulation (rTMS); Device: placebo rTMS | Transcranial Magnetic Stimulation for Tinnitus (NCT01104207) | Device: repetitive transcranial magnetic stimulation (rTMS); Device: placebo rTMS | Department of Veterans Affairs December 2014
Device: Bimodal Repetitive Transcranial Magnetic Stimulation | rTMS Bimodal Treatment For Tinnitus: A Pilot Study (NCT01590264) | Device: Bimodal Repetitive Transcranial Magnetic Stimulation | Washington University School of Medicine November 2012
Device: Repetitive Transcranial Magnetic Stimulation (rTMS) | Repetitive Transcranial Magnetic Stimulation for Tinnitus Treatment (NCT01093872) | Device: Repetitive Transcranial Magnetic Stimulation (rTMS) | Singapore General Hospital August 2013
Device: tVNS-Device | The Treatment of Tinnitus With Transcutaneous Non-invasive Vagus Nerve Stimulation (NCT01176734) | Device: tVNS-Device | cerbomed GmbH July 2012
Device: vagus nerve stimulation (VNS)
Device: rTMS | Repetitive Transcranial Magnetic Stimulation With Double Cone Coil in Chronic Tinnitus (Ti-CDC) (NCT01663311) | Device: Medial Frontal rTMS Double-Cone-Coil; Device: Left DLPFC Butterfly Coil | University of Regensburg December 2013
Device: Low frequency rTMS | rTMS for the Treatment of Chronic Tinnitus: Optimization by Simulation of the Cortical Tinnitus Network (Triple) (NCT01663324) | Device: Magventure Mag Pro Option | University of Regensburg March 2014

Table F3 Ongoing clinical trials evaluating psychological/behavioral interventions

Psych/Beh Intervention | Study Title (NCT number) | Intervention | Sponsor Completion date
CBT/CBT combination | Cognitive Behavioral Therapy (CBT) for Tinnitus (NCT00724152) | CBT/Education Training/Usual Care | Department of Veterans Affairs; Yale University January 2013
CBT/CBT combination | Treatment of Chronic Bothersome Tinnitus Using Cognitive Training and D-cycloserine (NCT01550796) | Behavioral: Cognitive Training; Drug: placebo | Washington University School of Medicine June 2012
Other psych/behavioral | Cognitive Training for Firefighters With Tinnitus (NCT01458821) | Brain Fitness Program - Tinnitus | Washington University School of Medicine; Federal Emergency Management Agency October 2013
Other psych/behavioral | Mindfulness Based Tinnitus Reduction (MBTR): A Symptom Perception Shift Program (NCT01229709) | Mindfulness Based Tinnitus Reduction/Treatment as Usual | University of California, San Francisco January 2015
Other psych/behavioral | Multi-Site Evaluation of Progressive Tinnitus Management (NCT01015781) | Progressive Tinnitus Management/Treatment as Usual | Department of Veterans Affairs June 2013
Other psych/behavioral | Telephone Tinnitus Education for Patients With Traumatic Brain Injury (TBI) (NCT01129141) | Telephone Tinnitus Education/Wait List Control | Department of Veterans Affairs September 2014
Other psych/behavioral | Neuro-Music Therapy for Recent Onset Tinnitus: Evaluation of a Therapy Concept (NCT01566708) | Neuro-Music Therapy immediately/after waiting time/Music-therapeutical stress management coaching | German Center for Music Therapy Research; University Hospital for Ear, Nose, and Throat, University of Heidelberg, Germany; Clinic of Diagnostic and Interventional Neuroradiology, Saarland University Clinic, Homburg, Germany July 2013
Other psych/behavioral | New Therapy for Patients With Severe Tinnitus (NCT01480193) | Other: Sound Based and Educational (SBE) Therapies; Other: Integrated Medicine Therapies and Sound Based Education Therapies; Other: Integrated Medicine Therapies and SBE | Duke University; National Institutes of Health (NIH); National Institute on Deafness and Other Communication Disorders (NIDCD) October 2013

Abbreviations: CBT = cognitive behavioural therapy

Table F4 Ongoing clinical trials evaluating sensory modulation or other devices

Devices Category | Study Title (NCT number) | Intervention | Sponsor Completion date
Coventional/Placebo Sound Generator | Tinnitus Retraining Therapy Trial (NCT01177137) | Coventional/Placebo Sound Generator (SG) | Johns Hopkins Bloomberg School of Public Health; National Institute on Deafness and Other Communication Disorders (NIDCD); University of Alabama, Tuscaloosa; David Grant U.S. Air Force Medical Center; Wilford Hall Medical Center; United States Naval Medical Center, San Diego; United States Naval Medical Center, Portsmouth; National Naval Medical Center; Naval Hospital Camp Pendleton February 2015
Device: CR Neuromodulation | Evaluation of the CR Neuromodulation Treatment for Tinnitus (NCT01541969) | Device: CR Neuromodulation | Nottingham University Hospitals NHS Trust; University of Nottingham; University College, London November 2013
Device: BrainSTIM Transcranial Stimulator | Transcranial Direct Current Stimulation (tDCS) for the Treatment of Tinnitus (NCT01575496) | Device: BrainSTIM Transcranial Stimulator | Centre Hospitalier Universitaire Vaudois January 2015
The Inhibitor™ Tinnitus Masking Device | Inhibitor Masking Device & SCN9 Gene Expression (NCT01412918) | The Inhibitor™ Tinnitus Masking Device | Medical College of Wisconsin December 2016
Device: P-Stim | Somatosensory Based Treatments for Tinnitus (NCT01066273) | Device: P-Stim | Massachusetts Eye and Ear Infirmary December 2015 - Withdrawn
Device: ANM T30 CR®-System | Acoustic Coordinated Reset (CR®) Neuromodulation for the Treatment of Chronic Tonal Tinnitus (“RESET Real Life”) (NCT01435317) | Device: ANM T30 CR®-System | ANM Adaptive Neuromodulation GmbH; Ceres GmbH evaluation & research July 2013
Device: Customized sound; Regular masker | Customized Acoustic Stimulation for the Treatment of Tinnitus (NCT01487447) | Device: Customized sound; Device: Regular masker | University of California, Irvine July 2012: this study is still recruiting participants
Device: Smartphone and web based TRT | Efficacy of Internet and Smartphone Application-delivered Tinnitus Retraining Therapy (NCT01663467) | Device: modified TRT using smartphone and web based materials; Drug: Gingko biloba | Seoul National University Hospital; Soonchunhyang University Hospital December 2013

Abbreviations: PSTIM = pulse stimulation treatment; TRT = Tinnitus Retraining Therapy