# Characteristics of Included Studies Evidence Tables

Table E1 Pharmacological or food supplement interventions and outcomes (n=16)

Table E2 Medical interventions and outcomes (n=11)

Table E3 Sound treatment/technologies intervention and outcomes (n=5)

Table E4 Psychological/behavioral intervention and outcomes (n=19)

## Appendix E. References

1 American Tinnitus Association. Top 10 most frequently asked questions. www.ata.org/for-patients/faqs. Accessed January 10, 2011.
2 Davis A, El Rafaie A. Epidemiology of tinnitus In: Epidemiology of tinnitus. Tyler RS, editor. San Diego, CA. Singular Publishing Group. 2000;1:1-24.
3 Press release: Two ATA Scientific Advisory Committee members receive Department of Defense grant. www.ata.org/about-ata/news-pubs/press-releases#DoDGrant. Accessed June 1, 2011.
4 Savage J, Cook S, Wadell A. Tinnitus Clin Evid. 2007. [pmid: 19454115].
5 Shargorodsky J, Curhan GC, Farwell WR. Prevalence and characteristics of tinnitus among US adults. Am J Med. 2010;123(8):711-8. [pmid: 20670725].
6 Zoger S, Erlandsson S, Svedlund J, et al. Benefits from group psychotherapy in the treatment of severe refractory tinnitus. Audiol Med. 2008;6(1):62-72.
7 Scott B, Lindberg P, Lyttkens L, et al. Psychological treatment of tinnitus. Scand Audiol. 1985;14(4):223-30. [pmid: 3912955].
8 Weber C, Arck P, Mazurek B, et al. Impact of a relaxation training on psychometric and immunologic parameters in tinnitus sufferers. J Psychosom Res. 2002;52(1):29-33. [pmid: 11801262].
9 Henry JA. 2011. Jul. 26. Key informant interview.
10 Henry JA, Zaugg TL, Myers PJ, et al. A triage guide for tinnitus. J Fam Pract. 2010;59(7):389-93. [pmid: 20625568].
11 Tinnitus: Guidelines for primary care. British Tinnitus Association. 2009. http://tinnitus.demonweb.co.uk/files/Tinnitus%20%20Guidelines%20for%20Primary%20Care.pdf. Accessed September 19, 2012.
12 Holgers K-M. Mechanisms and classification of tinnitus: A discussion paper. Audiol Med. 2003;1(4):238-41.
13 Kroner-Herwig B, Frenzel A, Fritsche G, et al. The management of chronic tinnitus: Comparison of an outpatient cognitive-behavioral group training to minimal-contact interventions. J Psychosom Res. 2003;54(4):381-9. [pmid: 12670617].
14 Weise C, Heinecke K, Rief W. Biofeedback-based behavioral treatment for chronic tinnitus: Results of a randomized controlled trial. J Consult Clin Psychol. 2008;76(6):1046-57. [pmid: 19045972].
15 Dobie RA. A review of randomized clinical trials in tinnitus. Laryngoscope. 1999;109(8):1202-11. [pmid: 10443820].
16 McCombe A, Baguley D, Coles R, et al. Guidelines for the grading of tinnitus severity: The results of a working group commissioned by the British Association of Otolaryngologists, Head and Neck Surgeons, 1999. Clin Otolaryngol Allied Sci. 2001;26(5):388-93. [pmid: 11678946].
17 Erlandsson S. Psychological profiles of tinnitus in patients. Tinnitus Handbook. Tyler RS, editor. San Diego, CA. Singular Publishing Group. 2000;2:25-58.
18 Figueiredo RR, Azevedo AA, Oliveira PM. Correlation analysis of the visual-analogue scale and the Tinnitus Handicap Inventory in tinnitus patients. Revista Brasil Otorrinolaringol. 2009;75(1):76-9. [pmid: 19488564].
19 Kamalski DM, Hoekstra CE, van Zanten BG, et al. Measuring disease-specific health-related quality of life to evaluate treatment outcomes in tinnitus patients: A systematic review. Otolaryngol Head Neck Surg. 2010;143(2):181-5. [pmid: 20647116].
20 Lipsey MW. Design sensitivity: Statistical power for experimental research. Newburry Park, CA. Sage Publications, Inc. 1990.
21 Kazdin AE. Research design in clinical psychology. 4th. Needham Heights, MA. Allyn & Bacon. 2003.
22 Meikle M, Henry JA, Griest S, et al. The Tinnitus Functional Index: Development of a new clinical measure for chronic, intrusive tinnitus. Ear Hear. 2011;32(5). [pmid: 22156949].
23 Baldo P, Doree C, Lazzarini R, et al. Antidepressants for patients with tinnitus. Cochrane Database Syst Rev. 2006;(4):CD003853. [pmid: 17054188].
24 Johnson RM, Brummett R, Schleuning A. Use of alprazolam for relief of tinnitus. A double-blind study. Arch Otolaryngol Head Neck Surg. 1993;119(8):842-5. [pmid: 8343245].
25 Jalali MM, Kousha A, Naghavi SE, et al. The effects of alprazolam on tinnitus: A cross-over randomized clinical trial. Med Sci Mon. 2009;15(11):I55-I60 P. [pmid: 19865063].
26 Kalcioglu MT, Bayindir T, Erdem T, et al. Objective evaluation of the effects of intravenous lidocaine on tinnitus. Hear Res. 2005;199(1–2):81-8. [pmid: 15574302].
27 Agarwal L, Pothier DD. Vasodilators and vasoactive substances for idiopathic sudden sensorineural hearing loss. Cochrane Database Syst Rev. 2009;(4):CD003422. [pmid: 19821308].
28 Noble W. Treatments for tinnitus. Trends Amplification. 2008;12(3):236-41. [pmid: 18635586].
29 Sziklai I, Szilvassy J, Szilvassy Z. Tinnitus control by dopamine agonist pramipexole in presbycusis patients: A randomized, placebo-controlled, double-blind study. Laryngoscope. 2011;121(4):888-93. [pmid: 21433025].
30 Hilton M, Stuart E. Ginkgo biloba for tinnitus. Cochrane Database Syst Rev. 2004;(2):CD003852. [pmid: 15106224].
31 Teggi R, Bellini C, Piccioni LO, et al. Transmeatal low-level laser therapy for chronic tinnitus with cochlear dysfunction. Audiol Neuro Otol. 2009;14(2):115-20. [pmid: 18843180].
32 Tuz HH, Onder EM, Kisnisci RS. Prevalence of otologic complaints in patients with temporomandibular disorder. Am J Orthod Dentofacial Orthop. 2003;123(6):620-3. [pmid: 12806339].
33 Wright EF, Syms CA III, Bifano SL. Tinnitus, dizziness, and nonotologic otalgia improvement through temporomandibular disorder therapy. Milit Med. 2000;165(10):733-6. [pmid: 11050868].
34 Ash CM, Pinto OF. The TMJ and the middle ear: Structural and functional correlates for aural symptoms associated with temporomandibular joint dysfunction. Int J Prosthodont. 1991;4(1):51-7. [pmid: 2012671].
35 Langguth B, Hajak G, Kleinjung T, et al. Repetitive transcranial magnetic stimulation and chronic tinnitus. Acta Otolaryngol Suppl. 2006;(556):102-5. [pmid: 17114153].
36 Henry JA, Dennis KC, Schechter MA. General review of tinnitus: Prevalence, mechanisms, effects, and management. J Speech Lang Hear Res. 2005;48(5):1204-35. [pmid: 16411806].
37 Park J, White AR, Ernst E. Efficacy of acupuncture as a treatment for tinnitus: A systematic review. Arch Otolaryngol Head Neck Surg. 2000;126(4):489-92. [pmid: 10772302].
38 Bennett M, Kertesz T, Yeung P. Hyperbaric oxygen therapy for idiopathic sudden sensorineural hearing loss and tinnitus: A systematic review of randomized controlled trials. J Laryngol Otol. 2005;119(10):791-8. [pmid: 16259656].
39 Keate B. Diet and tinnitus: What to eat … and what not to eat. Tinnitus Library. www.tinnitusformula.com/infocenter/articles/treatments/diet.aspx. Accessed June 10, 2011.
40 Tinnitus and your diet. New Tinnitus Treatments Blog. 2011. www.tinnitustreatments.org/tinnitus-and-your-diet.html. Accessed June 10, 2011.
41 Tinnitus relief through diet - Foods to avoid to relieve tinnitus. Tinnitus Remedies Web Site. 2011. www.thetinnitussite.info/tinnitus-relief-2/tinnitus-relief-through-diet-foods-to-avoid-to-relieve-tinnitus. Accessed June 10, 2011.
42 Henry JA, Zaugg TL, Myers PJ, et al. Progressive audiologic tinnitus management. ASHA Leader. 2008;13(8):14-7.
43 Hobson J, Chisholm E, El RA. Sound therapy (masking) in the management of tinnitus in adults. Cochrane Database Syst Rev. 2010;12:CD006371. [pmid: 21154366].
44 CIGNA medical coverage policy No. 0220. Tinnitus treatment services and devices. www.cigna.com/assets/docs/health-care-professionals/coverage_positions/mm_0220_coveragepositioncriteria_tinnitus_instr_devices_retraining_ther.pdf. Accessed June 10, 2011.
45 Davis PB, Wilde RA, Steed LG, et al. Treatment of tinnitus with a customized acoustic neural stimulus: A controlled clinical study. Ear Nose Throat J. 2008;87(6):330-9. [pmid: 18561116].
46 Davis PB, Paki B, Hanley PJ. Neuromonics tinnitus treatment: Third clinical trial. Ear Hear. 2007;28(2):242-59. [pmid: 17496674].
47 Langguth B, Kleinjung T, Landgrebe M. Tinnitus: The complexity of standardization. Eval Health Prof. 2011;34(4):429-33. [pmid: 21224265].
48 Martinez-Devesa P, Perera R, Theodoulou M, et al. Cognitive behavioural therapy for tinnitus. Cochrane Database Syst Rev. 2010;(9):CD005233. [pmid: 20824844].
49 Department of Health. Provision of services for adults with tinnitus: A good practice guide. London. Central Office of Information. 2009.
50 Phillips JS, McFerran D. Tinnitus Retraining Therapy (TRT) for tinnitus. Cochrane Database Syst Rev. 2010;(3):CD007330. [pmid: 20238353].
51 Jastreboff PJ, Hazell JW. A neurophysiological approach to tinnitus: Clinical implications. Br J Audiol. 1993;27(1):7-17. [pmid: 8339063].
52 Ireland CE, Wilson PH, Tonkin JP, et al. An evaluation of relaxation training in the treatment of tinnitus. Behav Res Ther. 1985;23(4):423-30. [pmid: 3896227].
53 Henry JA, Zaugg TL, Myers PJ, et al. The role of audiologic evaluation in progressive audiologic tinnitus management. Trends Amplification. 2008;12(3):170-87. [pmid: 18628281].
54 Cima RF, Maes IH, Joore MA, et al. Specialised treatment based on cognitive behaviour therapy versus usual care for tinnitus: A randomised controlled trial. Lancet. 2012;379(9830):1951-9. [pmid: 22633033].
55 Davis A, Smith P, Ferguson M, et al. Acceptability, benefit and costs of early screening for hearing disability: A study of potential screening tests and models. Health Technol Assess. 2007;11(42):iii-294. [pmid: 17927921].
56 Searchfield G. A commentary on the complexity of tinnitus management: Clinical guidelines provide a path through the fog. Eval Health Prof. 2011. [pmid: 21224266].
57 Hoare DJ, Gander PE, Collins L, et al. Management of tinnitus in English NHS audiology departments: An evaluation of current practice. J Eval Clin Pract. 2010. [pmid: 21087449].
58 Henry JA, Schechter MA, Loovis CL, et al. Clinical management of tinnitus using a “progressive intervention” approach. J Rehabil Res Dev. 2005;42(4:Suppl 2):95-116. [pmid: 16470467].
59 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: Empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
60 Moher D, Pham B, Klassen T, et al. What contributions do languages other than English make on the results of meta-analysis?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
61 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOW) for assessing the quality of nonrandomised studies in meta-analyses. www.ohri.ca/ programs/clinical_epidemiology/oxford.asp. Accessed September 19, 2012.
62 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
63 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
64 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines: 7. Rating the quality of evidence--inconsistency. J Clin Epidemiol. 2011;64(12):1294-302. [pmid: 21803546].
65 Martinez DP, Perera R, Theodoulou M, et al. Cognitive behavioural therapy for tinnitus. Cochrane Database Syst Rev. 2010;(2):CD005233. [pmid: 20824844].
66 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
67 Grading the strength of a body of evidence when assessing health care interventions: An update. [Draft]. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
68 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-37. [pmid: 16549855].
69 Guyatt GH, Oxman AD, Montori V, et al. GRADE guidelines: 5. Rating the quality of evidence--publication bias. J Clin Epidemiol. 2011;64(12):1277-82. [pmid: 21802904].
70 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: The PRISMA statement. Ann Intern Med. 2009;151(4):264-9. W64. [pmid: 19622511].
71 Abbott JA, Kaldo V, Klein B, et al. A cluster randomised trial of an internet-based intervention program for tinnitus distress in an industrial setting. Cognit Behav Ther. 2009;38(3):162-73. [pmid: 19675959].
72 Azevedo AA, Figueiredo RR. Tinnitus treatment with acamprosate: Double-blind study. Revista Brasil Otorrinolaringol. 2005;71(5):618-23. [pmid: 16612523].
73 Anders M, Dvorakova J, Rathova L, et al. Efficacy of repetitive transcranial magnetic stimulation for the treatment of refractory chronic tinnitus: A randomized, placebo controlled study. Neuroendocrinol Lett. 2010;31(2):238-49. [pmid: 20424590].
74 Andersson G, Stromgren T, Strom L, et al. Randomized controlled trial of internet-based cognitive behavior therapy for distress associated with tinnitus. Psychosom Med. 2002;64(5):810-6. [pmid: 12271112].
75 Andersson G, Porsaeus D, Wiklund M, et al. Treatment of tinnitus in the elderly: A controlled trial of cognitive behavior therapy. Int J Audiol. 2005;44(11):671-5. [pmid: 16379495].
76 Aoki M, Wakaoka Y, Hayashi H, et al. Effect of lyophilized powder made from enzymolyzed honeybee larvae on tinnitus-related symptoms, hearing levels, and hypothalamus-pituitary-adrenal axis-related hormones. Ear Hear. 2012;33(3):430-6. [pmid: 21971082].
77 Arda HN, Tuncel U, Akdogan O, et al. The role of zinc in the treatment of tinnitus. Otol Neurotol. 2003;24(1):86-9. [pmid: 12544035].
78 Biesinger E, Kipman U, Schatz S, et al. Qigong for the treatment of tinnitus: A prospective randomized controlled study. J Psychosom Res. 2010;69(3):299-304. [pmid: 20708452].
79 Chung HK, Tsai CH, Lin YC, et al. Effectiveness of theta-burst repetitive transcranial magnetic stimulation for treating chronic tinnitus. Audiol Neuro Otol. 2012;17(2):112-20. [pmid: 21865723].
80 Cuda D, De CA. Effectiveness of combined counseling and low-level laser stimulation in the treatment of disturbing chronic tinnitus. Int Tinnitus J. 2008;14(2):175-80. [pmid: 19205171].
81 Dib GC, Kasse CA, Alves de AT, et al. Tinnitus treatment with Trazodone. Revista Brasil Otorrinolaringol. 2007;73(3):390-7. [pmid: 17684661].
82 Dineen R, Doyle J, Bench J. Managing tinnitus: A comparison of different approaches to tinnitus management training. Br J Audiol. 1997;31(5):331-44. [pmid: 9373742].
83 Dineen R, Doyle J, Bench J, et al. The influence of training on tinnitus perception: An evaluation 12 months after tinnitus management training. Br J Audiol. 1999;33(1):29-51. [pmid: 10219721].
84 Drew S, Davies E. Effectiveness of Ginkgo biloba in treating tinnitus: Double blind, placebo controlled trial. BMJ. 2001;322(7278):73. [pmid: 11154618].
85 Ghossaini SN, Spitzer JB, Mackins CC, et al. High-frequency pulsed electromagnetic energy in tinnitus treatment. Laryngoscope. 2004;114(3):495-500. [pmid: 15091224].
86 Henry JL, Wilson PH. The psychological management of tinnitus: Comparison of a combined cognitive educational program, education alone and a waiting list control. Int Tinnitus J. 1996;2:9-20. [pmid: 10753339].
87 Henry JL, Wilson PH. An evaluation of two types of cognitive intervention in the management of chronic tinnitus. Scand J Behav Ther. 1998;27(4):156-66.
88 Henry JA, Loovis C, Montero M, et al. Randomized clinical trial: Group counseling based on tinnitus retraining therapy. J Rehabil Res Dev. 2007;44(1):21-32. [pmid: 17551855].
89 Hiller W, Haerkotter C. Does sound stimulation have additive effects on cognitive-behavioral treatment of chronic tinnitus?. Behav Res Ther. 2005;43(5):595-612. [pmid: 15865915].
90 Holgers K-M, Zoger S, Svedlund J. The impact of sertraline on health-related quality of life in severe refractory tinnitus: A double-blind, randomized, placebo-controlled study. Audiol Med. 2011;9(2):67-72.
91 Kaldo V, Cars S, Rahnert M, et al. Use of a self-help book with weekly therapist contact to reduce tinnitus distress: A randomized controlled trial. J Psychosom Res. 2007;63(2):195-202. [pmid: 17662757].
92 Kaldo V, Levin S, Widarsson J, et al. Internet versus group cognitive-behavioral treatment of distress associated with tinnitus: A randomized controlled trial. Behav Ther. 2008;39(4):348-59. [pmid: 19027431].
93 Kroner-Herwig B, Hebing G, van Rijn-Kalkmann U, et al. The management of chronic tinnitus--Comparison of a cognitive-behavioural group training with yoga. J Psychosom Res. 1995;39(2):153-65. [pmid: 7595873].
94 Langguth B, Kleinjung T, Frank E, et al. High-frequency priming stimulation does not enhance the effect of low-frequency rTMS in the treatment of tinnitus. Exp Brain Res. 2008;184(4):587-91. [pmid: 18066684].
95 Malouff JM, Noble W, Schutte NS, et al. The effectiveness of bibliotherapy in alleviating tinnitus-related distress. J Psychosom Res. 2010;68(3):245-51. [pmid: 20159209].
96 Marcondes RA, Sanchez TG, Kii MA, et al. Repetitive transcranial magnetic stimulation improve tinnitus in normal hearing patients: A double-blind controlled, clinical and neuroimaging outcome study. Eur J Neurol. 2010;17(1):38-44. [pmid: 19614962].
97 Mazurek B, Haupt H, Szczepek AJ, et al. Evaluation of vardenafil for the treatment of subjective tinnitus: A controlled pilot study. J Negative Results Biomed. 2009;8:3. [pmid: 19222841].
98 Meeus O, De RD, Van de Heyning P. Administration of the combination clonazepam-Deanxit as treatment for tinnitus. Otol Neurotol. 2011;32(4):701-9. [pmid: 21358561].
99 Mirz F, Zachariae R, Andersen SE, et al. The low-power laser in the treatment of tinnitus. Clin Otolaryngol Allied Sci. 1999;24(4):346-54. [pmid: 10472473].
100 Parazzini M, Del B, Jastreboff M, et al. Open ear hearing aids in tinnitus therapy: An efficacy comparison with sound generators. Int J Audiol. 2011;50(8):548-53. www.cinahl.com/cgi-bin/refsvc?jid=2576&accno=2011208063. [pmid: 21595527].
101 Piccirillo JF, Finnell J, Vlahiotis A, et al. Relief of idiopathic subjective tinnitus: Is gabapentin effective?. Arch Otolaryngol Head Neck Surg. 2007;133(4):390-7. [pmid: 17438255].
102 Plewnia C, Vonthein R, Wasserka B, et al. Treatment of chronic tinnitus with theta burst stimulation: A randomized controlled trial. Neurology. 2012;78(21):1628-34. [pmid: 22539568].
103 Rejali D, Sivakumar A, Balaji N. Ginkgo biloba does not benefit patients with tinnitus: A randomized placebo-controlled double-blind trial and meta-analysis of randomized trials. Clin Otolaryngol Allied Sci. 2004;29(3):226-31. [pmid: 15142066].
104 Rief W, Weise C, Kley N, et al. Psychophysiologic treatment of chronic tinnitus: A randomized clinical trial. Psychosom Med. 2005;67(5):833-8. [pmid: 16204446].
105 Robinson SK, Viirre ES, Bailey KA, et al. Randomized placebo-controlled trial of a selective serotonin reuptake inhibitor in the treatment of nondepressed tinnitus subjects. Psychosom Med. 2005;67(6):981-8. [pmid: 16314604].
106 Sharma DK, Kaur S, Singh J, et al. Role of acamprosate in sensorineural tinnitus. Indian J Pharmacol. 2012;44(1):93-6. [pmid: 22345878].
107 Sullivan M, Katon W, Russo J, et al. A randomized trial of nortriptyline for severe chronic tinnitus. Effects on depression, disability, and tinnitus symptoms. Arch Intern Med. 1993;153(19):2251-9. [pmid: 8215728].
108 Tass PA, Adamchic I, Freund H-J, et al. Counteracting tinnitus by acoustic coordinated reset neuromodulation. Restor Neurol Neurosci. 2012;30(2):137-59. [pmid: 22414611].
109 Topak M, Sahin-Yilmaz A, Ozdoganoglu T, et al. Intratympanic methylprednisolone injections for subjective tinnitus. J Laryngol Otol. 2009;123(11):1221-5. [pmid: 19640315].
110 Vilholm OJ, Moller K, Jorgensen K. Effect of traditional Chinese acupuncture on severe tinnitus: A double-blind, placebo-controlled, clinical investigation with open therapeutic control. Br J Audiol. 1998;32(3):197-204. [pmid: 9710337].
111 Westerberg BD, Roberson JB Jr, Stach BA. A double-blind placebo-controlled trial of baclofen in the treatment of tinnitus. Am J Otol. 1996;17(6):896-903. [pmid: 8915419].
112 Westin VZ, Schulin M, Hesser H, et al. Acceptance and commitment therapy versus tinnitus retraining therapy in the treatment of tinnitus: A randomised controlled trial. Behav Res Ther. 2011;49(11):737-47. [pmid: 21864830].
113 Zachriat C, Kroner-Herwig B. Treating chronic tinnitus: Comparison of cognitive-behavioural and habituation-based treatments. Cognit Behav Ther. 2004;33(4):187-98. [pmid: 15625793].
114 Zoger S, Svedlund J, Holgers KM. The effects of sertraline on severe tinnitus suffering--A randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2006;26(1):32-9. [pmid: 16415703].
115 Neri G, De SA, Baffa C, et al. Treatment of central and sensorineural tinnitus with orally administered Melatonin and Sulodexide: Personal experience from a randomized controlled study. Acta Otorhinolaryngol Ital. 2009;29(2):86-91. [pmid: 20111618].
116 Figueiredo RR, Langguth B, Mello de OP, et al. Tinnitus treatment with memantine. Otolaryngol Head Neck Surg. 2008;138(4):492-6. [pmid: 18359360].
117 Akkuzu B, Yilmaz I, Cakmak O, et al. Efficacy of misoprostol in the treatment of tinnitus in patients with diabetes and/or hypertension. Auris Nasus Larynx. 2004;31(3):226-32. [pmid: 15364356].
118 Bayar N, Boke B, Turan E, et al. Efficacy of amitriptyline in the treatment of subjective tinnitus. J Otolaryngol. 2001;30(5):300-3. [pmid: 11771024].
119 Dobie RA, Sakai CS, Sullivan MD, et al. Antidepressant treatment of tinnitus patients: Report of a randomized clinical trial and clinical prediction of benefit. Am J Otol. 1993;14(1):18-23. [pmid: 8424470].
120 Suckfüll M, Althaus M, Ellers-Lenz B, et al. A randomized, double-blind, placebo-controlled clinical trial to evaluate the efficacy and safety of neramexane in patients with moderate to severe subjective tinnitus. BMC Ear Nose Throat Disord. 2011;11(1).
121 Dehkordi MA, Abolbashari S, Taheri R, et al. Efficacy of gabapentin on subjective idiopathic tinnitus: A randomized, double-blind, placebo-controlled trial. Ear Nose Throat J. 2011;90(4).
122 Jakes SC, Hallam RS, McKenna L, et al. Group cognitive therapy for medical patients: An application to tinnitus. Cognit Ther Res. 1992;16:67-82. 1992:67–82.
123 Herraiz C, Diges I, Cobo P, et al. Auditory discrimination training for tinnitus treatment: The effect of different paradigms. Eur Arch Otorhinolaryngol. 2010;267(7):1067-74. [pmid: 20044759].
124 Olzowy B, Canis M, Hempel JM, et al. Effect of atorvastatin on progression of sensorineural hearing loss and tinnitus in the elderly: Results of a prospective, randomized, double-blind clinical trial. Otol Neurotol. 2007;28(4):455-8. [pmid: 17529847].
125 Searchfield GD, Kaur M, Martin WH. Hearing aids as an adjunct to counseling: Tinnitus patients who choose amplification do better than those that don’t. Int J Audiol. 2010;49(8):574-9. [pmid: 20500032].
126 Mason JD, Rogerson DR, Butler JD. Client centred hypnotherapy in the management of tinnitus--Is it better than counselling?. J Laryngol Otol. 1996;110(2):117-20. [pmid: 8729491].
127 Pandey S, Mahato NK, Navale R. Role of self-induced sound therapy: Bhramari Pranayama in Tinnitus. Audiol Med. 2010;8(3):137-41.
128 Erlandsson SI, Rubinstein B, Carlsson SG. Tinnitus: Evaluation of biofeedback and stomatognathic treatment. Br J Audiol. 1991;25(3):151-61. [pmid: 1873582].
129 Bonaconsa A, Mazzoli MM, Antonia M, et al. Posturography measures and efficacy of different physical treatments in somatic tinnitus. Int Tinnitus J. 2010;16(1):44-50. [pmid: 21609913].
130 Neri G, Baffa C, De SA, et al. Management of tinnitus: Oral treatment with melatonin and sulodexide. Journal of Biological Regulators & Homeostatic Agents. 2009;23(2):103-10. [pmid: 19589291].
131 Lindberg P, Scott B, Melin L, et al. The psychological treatment of tinnitus: An experimental evaluation. Behav Res Ther. 1989;27(6):593-603. [pmid: 2692553].
132 Gungor A, Dogru S, Cincik H, et al. Effectiveness of transmeatal low power laser irradiation for chronic tinnitus. J Laryngol Otol. 2008;122(5):447-51. [pmid: 17625032].
133 Roland NJ, Hughes JB, Daley MB, et al. Electromagnetic stimulation as a treatment of tinnitus: A pilot study. Clin Otolaryngol Allied Sci. 1993;18(4):278-81. [pmid: 8877185].
134 Khedr EM, Rothwell JC, Ahmed MA, et al. Effect of daily repetitive transcranial magnetic stimulation for treatment of tinnitus: Comparison of different stimulus frequencies. J Neurol Neurosurg Psychiatry. 2008;79(2):212-5. [pmid: 18202212].
135 Podoshin L, Ben-David Y, Fradis M, et al. Idiopathic subjective tinnitus treated by biofeedback, acupuncture and drug therapy. Ear Nose Throat J. 1991;70(5):284-9. [pmid: 1914952].
136 Loke YK, Price D, Herxheimer A. Systematic reviews of adverse effects: Framework for a structured approach. BMC Med Res Methodol. 2007;7:32. [pmid: 17615054].
137 Montori VM, Guyatt GH. Intention-to-treat principle. CMAJ. 2001;165(10):1339-41. [pmid: 11760981].
138 Klockhoff I, Lindblom U. Meniere’s disease and hydrochlorothiazide (Dichlotride)--A critical analysis of symptoms and therapeutic effects. Acta Otolaryngol. 1967;63(4):347-65. [pmid: 6033658].
139 Geyh S, Cieza A, Schouten J, et al. ICF. Core Sets for stroke. J Rehabil Med. 2004;(44 Suppl):135-41. [pmid: 15370761].
140 Meng Z, Liu S, Zheng Y, et al. Repetitive transcranial magnetic stimulation for tinnitus. Cochrane Database Syst Rev. 2011;(10):CD007946. [pmid: 21975776].
141 Savage J, Waddell A. Tinnitus. Clinical Evidence. 2012;2012:2012. [pmid: 22331367].
142 Hoare DJ, Kowalkowski VL, Kang S, et al. Systematic review and meta-analyses of randomized controlled trials examining tinnitus management. Laryngoscope. 2011;121(7):1555-64. [pmid: 21671234].
143 Hesser H, Weise C, Westin VZ, et al. A systematic review and meta-analysis of randomized controlled trials of cognitive-behavioral therapy for tinnitus distress. Clinical Psychology Review. 2011;31(4):545-53. [pmid: 21237544].
144 Kochkin S, Tyler R, Born J. MarkeTrak VIII: The prevalence of tinnitus in the United States and the self-reported efficacy of various treatments. Hear Rev. 2011;18(12):10-27.
145 Nondahl DM, Cruickshanks KJ, Huang GH, et al. Generational differences in the reporting of tinnitus. Ear Hear. 2012;33(5):640-4. [pmid: 22588269].
146 Hoekstra CE, Rynja SP, van Zanten GA, et al. Anticonvulsants for tinnitus. Cochrane Database Syst Rev. 2011;(7):CD007960. [pmid: 21735419].
147 Karkos PD, Leong SC, Arya AK, et al. ‘Complementary ENT’: A systematic review of commonly used supplements. J Laryngol Otol. 2007;121(8):779-82. [pmid: 17125579].
148 Hilton, Malcolm P, Stuart, et al. Ginkgo biloba for tinnitus. Cochrane Database Syst Rev. 2010;(3).
149 Baldo, Paolo, Doree, et al. Antidepressants for patients with tinnitus. Cochrane Database Syst Rev. 2009;(1).
150 Ioannidis JPA, Evans SJW, Gotzsche PC, et al. Better reporting of harms in randomized trials: An extension of the CONSORT statement. Ann Intern Med. 2004;141(10):781-8. [pmid: 15545678].