# Publications Not Eligible for Extraction

Table D1 Pharmacological or food supplement interventions and outcomes: Honorable mention group (n=10)

Pharm/Food Intervention | # | Specific Intervention | Tinnitus-Specific QoL | Loudness | Sleep | Anxiety Symptoms | Depression Symptoms | Global QoL | Adverse Effects
Antidepressant drugs | | INACTIVE COMPARATOR
Antidepressant drugs | 1 | Amitriptyline vs. Placebo Bayar, 2001^1^ | ATA-Q
Antidepressant drugs | 2 | Nortriptyline vs. Placebo Dobie, 1993^2^ | IOWA, Tinnitus interference (self-report), | Self-reported | HDS subscale | HAS, Sheehan’s Disability Scale | BDI, HDS
Psychoactive (Neurotransmitter) drugs | | INACTIVE COMPARATOR
Psychoactive (Neurotransmitter) drugs | 1 | Gabapentin (GABA analogue – GABAergic) vs. placebo Dehkordi, 2011^3^ | TSI | subjective
Other drugs | | INACTIVE COMPARATOR
Other drugs | 1 | Melatonin and Sulodexide vs. control group Neri, 2009^4,5^ | THI
Other drugs | 2 | Melatonin alone vs. control group Neri, 2009^4,5^ | THI
Other drugs | 3 | Memantine vs. Placebo Figueiredo, 2008^6^ | THI
Other drugs | 4 | Atorvastatin vs. Placebo Olzowy, 2007^7^ | Tinnitus Score
Other drugs | 5 | Misoprostol vs. Placebo Akkuzu, 2004^8^ | Self-reported | Self-reported | Self-reported
Other drugs | 6 | Cinnarizine vs. Placebo Podoshin, 1991^9^ | Self-reported
Other drugs | 7 | Neramexane vs. Placebo Suckfüll, 2011^10^ | THI, TA (annoyance) | Likert-scale | | | | Likert-scale
Other drugs | 8 | AM-101 injection vs. Placebo Muehlmeier, 2011^11^ | THI | subjective
Other drugs | | HEAD TO HEAD
Other drugs | 1 | Melatonin and Sulodexide vs. Melatonin alone Neri, 2009^4,5^ | THI
Other drugs | 2 | Cinnarizine vs. Biofeedback Podoshin, 1991^9^ | Self-reported
Other drugs | 3 | Cinnarizine vs. Acupuncture Podoshin, 1991^9^ | Self-reported

Abbreviations: GABAB1 = gamma-aminobutyric acid B1; gen = generation; med/surg = medical/surgical; PDE5 = phosphodiesterase type 5; QoL = quality of life; rTMS = repetitive transcranial magnetic stimulation; SARI = serotonin antagonist reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; vs. = versus

Table D2 Medical interventions and outcomes: Honorable mention group (n=4)

Medical Intervention | # | Specific Intervention | Tinnitus-Specific QoL | Loudness | Sleep | Anxiety Symptoms | Depression Symptoms | Global QoL | Adverse Events
RTMS | | INACTIVE COMPARATOR
RTMS | 1 | 1Hz rTMS vs. sham Khedr, 2007^12^ | THI, self-reported
RTMS | 2 | 10Hz rTMS vs. sham Khedr, 2007^12^ | THI, self-reported
RTMS | 3 | 25Hz rTMS vs. sham Khedr, 2007^12^ | THI, self-reported
RTMS | 4 | Electromagnetic stimulation vs. Placebo Roland, 1993^13^ | Self-reported
RTMS | | HEAD TO HEAD
RTMS | 1 | 1Hz rTMS vs. 10Hz rTMS Khedr, 2007^12^ | THI, self-reported
RTMS | 2 | 1Hz rTMS vs. 25Hz rTMS Khedr, 2007^12^ | THI, self-reported
RTMS | 3 | 10Hz rTMS vs. 25Hz rTMS Khedr, 2007^12^ | THI, self-reported
Neuromodulation | | HEAD TO HEAD
Neuromodulation | 1 | InterX (electrical neuro stimulation) vs. Osteopathic manipulations Bonaconsa, 2010^14^ | THI, VAS
Laser | | INACTIVE COMPARATOR
Laser | 1 | Laser therapy vs. Placebo Gungor, 2008^15^ | Self-reported | Self-reported

Table D3 Sound treatments/technologies interventions and outcomes: Honorable mention group (n=4)

Sound Treatment/Technology | # | Specific Intervention | Tinnitus-Specific QoL | Loudness | Sleep | Anxiety Symptoms | Depression Symptoms | Global QoL | Adverse Events
| | INACTIVE COMPARATOR
| 1 | HLSAME ADT vs. WLG Herraiz, 2010, 16 | THI | VAS
| 2 | HLNONSAME ADT vs. WLG Herraiz, 2010, 16 | THI | VAS
| 3 | Aural masker vs. placebo masker Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale
| 4 | Group cognitive therapy + aural masker vs. placebo masker Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale
| | HEAD TO HEAD
| 1 | HLSAME ADT vs. HLNONSAME ADT Herraiz, 2010, 16 | THI | VAS
| 2 | Hearing aid plus counselling vs. counselling only Searchfield, 2010, 18 | THQ
| 3 | Tinnitus Masking vs. pharmacotherapy Pandey, 2010, 19 | THI | | | HAS | HAD
| 4 | Tinnitus Masking vs. yoga (Bhramari Pranayama) Pandey, 2010, 19 | THI | | | HAS | HAD
| 5 | Tinnitus Masking vs. combination therapy Pandey, 2010, 19 | THI | | | HAS | HAD
| 6 | Aural masker vs. Group cognitive therapy + aural masker Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale

Table D4 Psychological/behavioral interventions and outcome measures: Honorable mention group (n=6)

Psych/Beh Intervention | # | Specific Intervention | Tinnitus-Specific QoL | Loudness | Sleep | Anxiety Symptoms | Depression Symptoms | Global QoL | Adverse Events
CBT/CBT combination | | INACTIVE COMPARISONS
CBT/CBT combination | 1 | Group cognitive therapy vs. WLC Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale
CBT/CBT combination | 2 | Group cognitive therapy + aural masker vs. WLC Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale
CBT/CBT combination | | HEAD TO HEAD COMPARISONS
CBT/CBT combination | | Group cognitive therapy vs. Group cognitive therapy + aural masker Jakes, 1992, 17 | TEQ, IWDA, CCEI | | TEQ-sub scale
Relaxatio n | | INACTIVE COMPARATOR
Relaxatio n | 1 | Relaxation & exposure vs. WLC Lindberg, 1989, 20 | Tinnitus control (VAS), discomfort (VAS) | VAS
Relaxatio n | 2 | Relaxation & distraction vs. WLC Lindberg, 1989, 20 | Tinnitus control (VAS), discomfort (VAS) | VAS
Relaxatio n | | HEAD to HEAD
Relaxatio n | 1 | Relaxation & distraction vs. Relaxation & exposure Lindberg, 1989, 20 | Tinnitus control (VAS), discomfort (VAS | VAS
Other psych/beh | | INACTIVE COMPARATOR
Other psych/beh | 1 | Biofeedback vs. Control Podoshin, 1991, 9 | Self-reported
Other psych/beh | | HEAD TO HEAD
Other psych/beh | 1 | yoga (Bhramari Pranayama) vs. pharmacotherapy Pandey, 2010, 19 | THI | | | HAS | HAD
Other psych/beh | 2 | yoga (Bhramari Pranayama) vs. combination therapy Pandey, 2010, 19 | THI | | | HAS | HAD
Other psych/beh | 3 | Client centered hypnotherapy vs. counseling Mason, 1996, 21 | TSSS
Other psych/beh | 4 | Biofeedback vs. Stomatognathic treatment Erlandsson, 1991, 22 | Self-reported

Abbreviations: ACT = acceptance and commitment therapy; CBT = cognitive behavioral training; psych/beh = psychological/behavioral; EMG = electromyography; TCT tinnitus coping therapy; TRT = tinnitus retraining therapy; vs. = versus; WLC = wait list control

## Appendix D. References

1 Bayar N, Boke B, Turan E, et al. Efficacy of amitriptyline in the treatment of subjective tinnitus. J Otolaryngol. 2001;30(5):300-3. [pmid: 11771024].
2 Dobie RA, Sakai CS, Sullivan MD, et al. Antidepressant treatment of tinnitus patients: Report of a randomized clinical trial and clinical prediction of benefit. Am J Otol. 1993;14(1):18-23. [pmid: 8424470].
3 Dehkordi MA, Abolbashari S, Taheri R, et al. Efficacy of gabapentin on subjective sidiopathic tinnitus: A randomized, double-blind, placebo-controlled trial. Ear Nose Throat J. 2011;90(4):150-8. [pmid: 21500166].
4 Neri G, De SA, Baffa C, et al. Treatment of central and sensorineural tinnitus with orally administered Melatonin and Sulodexide: Personal experience from a randomized controlled study. Acta Otorhinolaryngol Ital. 2009;29(2):86-91. [pmid: 20111618].
5 Neri G, Baffa C, De SA, et al. Management of tinnitus: Oral treatment with melatonin and sulodexide. Journal of Biological Regulators & Homeostatic Agents. 2009;23(2):103-10. [pmid: 19589291].
6 Figueiredo RR, Langguth B, Mello de OP, et al. Tinnitus treatment with memantine. Otolaryngol Head Neck Surg. 2008;138(4):492-6. [pmid: 18359360].
7 Olzowy B, Canis M, Hempel JM, et al. Effect of atorvastatin on progression of sensorineural hearing loss and tinnitus in the elderly: Results of a prospective, randomized, double-blind clinical trial. Otol Neurotol. 2007;28(4):455-8. [pmid: 17529847].
8 Akkuzu B, Yilmaz I, Cakmak O, et al. Efficacy of misoprostol in the treatment of tinnitus in patients with diabetes and/or hypertension. Auris Nasus Larynx. 2004;31(3):226-32. [pmid: 15364356].
9 Podoshin L, Ben-David Y, Fradis M, et al. Idiopathic subjective tinnitus treated by biofeedback, acupuncture and drug therapy. Ear Nose Throat J. 1991;70(5):284-9. [pmid: 1914952].
10 Suckfüll M, Althaus M, Ellers-Lenz B, et al. A randomized, double-blind, placebo-controlled clinical trial to evaluate the efficacy and safety of neramexane in patients with moderate to severe subjective tinnitus. BMC Ear Nose Throat Disord. 2011;11(1):1. [pmid: 21223542].
11 Muehlmeier G, Biesinger E, Maier H. Safety of intratympanic injection of AM-101 in patients with acute inner ear tinnitus. Audiol Neuro Otol. 2011;16(6):388-97. [pmid: 21252501].
12 Khedr EM, Rothwell JC, Ahmed MA, et al. Effect of daily repetitive transcranial magnetic stimulation for treatment of tinnitus: Comparison of different stimulus frequencies. J Neurol Neurosurg Psychiatry. 2008;79(2):212-5. [pmid: 18202212].
13 Roland NJ, Hughes JB, Daley MB, et al. Electromagnetic stimulation as a treatment of tinnitus: A pilot study. Clin Otolaryngol Allied Sci. 1993;18(4):278-81. [pmid: 8877185].
14 Bonaconsa A, Mazzoli MM, Antonia M, et al. Posturography measures and efficacy of different physical treatments in somatic tinnitus. Int Tinnitus J. 2010;16(1):44-50. [pmid: 21609913].
15 Gungor A, Dogru S, Cincik H, et al. Effectiveness of transmeatal low power laser irradiation for chronic tinnitus. J Laryngol Otol. 2008;122(5):447-51. [pmid: 17625032].
16 Herraiz C, Diges I, Cobo P, et al. Auditory discrimination training for tinnitus treatment: The effect of different paradigms. Eur Arch Otorhinolaryngol. 2010;267(7):1067-74. [pmid: 20044759].
17 Jakes SC, Hallam RS, McKenna L, et al. Group cognitive therapy for medical patients: An application to tinnitus. Cognit Ther Res. 1992;16(1):67-82.
18 Searchfield GD, Kaur M, Martin WH. Hearing aids as an adjunct to counseling: Tinnitus patients who choose amplification do better than those that don’t. Int J Audiol. 2010;49(8):574-9. [pmid: 20500032].
19 Pandey S, Mahato NK, Navale R. Role of self-induced sound therapy: Bhramari Pranayama in Tinnitus. Audiol Med. 2010;8(3):137-41.
20 Lindberg P, Scott B, Melin L, et al. The psychological treatment of tinnitus: An experimental evaluation. Behav Res Ther. 1989;27(6):593-603. [pmid: 2692553].
21 Mason JD, Rogerson DR, Butler JD. Client centred hypnotherapy in the management of tinnitus--Is it better than counselling?. J Laryngol Otol. 1996;110(2):117-20. [pmid: 8729491].
22 Erlandsson SI, Rubinstein B, Carlsson SG. Tinnitus: Evaluation of biofeedback and stomatognathic treatment. Br J Audiol. 1991;25(3):151-61. [pmid: 1873582].