# Excluded Studies

Aazh H, Moore BCJ, Glasberg BR. Simplified form of tinnitus retraining therapy in adults: A retrospective study. BMC Ear Nose Throat Disord. 2008;8(1):7. Exclude: Non-randomized head-to-head. [pmid: 18980672].
Abelson TI. Long-term bilateral tinnitus. JAMA. 1985;253(19):2830. Exclude: Not a primary study. [pmid: 3989951].
Acrani IO, Pereira LD. Temporal resolution and selective attention of individuals with tinnitus. Profono. 2010;22(3):233-8. Exclude: Only determined various effects. [pmid: 21103711].
Adlington P, Warrick J. Stellate ganglion block in the management of tinnitus. J Laryngol Otol. 1971;85(2):159-68. Exclude: Case study or series. [pmid: 4396190].
Ahmad R, Raichura N, Kilbane V, et al. Vancomycin: A reappraisal. BMJ Clin Res Ed. 1982;284(6333):1953-4. Exclude: Not a primary study. [pmid: 6805786].
Ahmad S. Venlafaxine and severe tinnitus. Am Fam Physician. 1995;51(8):1830. Exclude: Not a primary study. [pmid: 7762476].
Albrecht CR III, Gambert SR. Botanical and diet-based biological therapies and their use by older persons: Part I. Clin Geriatr. 2005;13(1):26-34. Exclude: Not a primary study.
Aleksic M, Schutz G, Gerth S, et al. Surgical approach to kinking and coiling of the internal carotid artery. J Cardiovasc Surg. 2004;45(1):43-8. Exclude: Tinnitus is somatic. [pmid: 15041936].
Al-Jassim AH. The use of Walkman Mini-stereo system as a tinnitus masker. J Laryngol Otol. 1988;102(1):27-8. Exclude: Non-randomized head-to-head. [pmid: 3343558].
Almeida TA, Samelli AG, Mecca FN, et al. Tinnitus sensation pre and post nutritional intervention in metabolic disorders. Profono. 2009;21(4):291-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20098946].
Andersson G, Airikka M-L, Buhrman M, et al. Dimensions of perfectionism and tinnitus distress. Psychol Health Med. 2005;10(1):78-87. Exclude: Only determined various effects.
Andersson G, Edsjo L, Kaldo V, et al. Tinnitus and short-term serial recall in stable versus intermittent masking conditions. Scand J Psychol. 2009;50(5):517-22. Exclude: Only determined various effects. [pmid: 19778399].
Andersson G, Ingerholt C, Jansson M. Autobiographical memory in patients with tinnitus. Psychol Health. 2003;18(5):667-75. Exclude: Only determined various effects.
Andersson G, Juris L, Classon E, et al. Consequences of suppressing thoughts about tinnitus and the effects of cognitive distraction on brain activity in tinnitus patients. Audiol Neuro Otol. 2006;11(5):301-9. Exclude: Only determined various effects. [pmid: 16837798].
Andersson G, Kaldo V, Stromgren T, et al. Are coping strategies really useful for the tinnitus patient? An investigation conducted via the internet. Audiol Med. 2004;2(1):54-9. Exclude: Only about prevalence.
Andersson G, Keshishi A, Baguley DM. Benefit from hearing aids in users with and without tinnitus. Audiol Med. 2011;9(2):73-8. Exclude: Non-randomized head-to-head.
Andersson G, Kyrre SO, Kaldo V, et al. Future thinking in tinnitus patients. J Psychosom Res. 2007;63(2):191-4. Exclude: Only determined various effects. [pmid: 17662756].
Andersson G. Prior treatments in a group of tinnitus sufferers seeking treatment. Psychother Psychosom. 1997;66(2):107-10. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9097339].
Andersson G. The role of optimism in patients with tinnitus and in patients with hearing impairment. Psychol Health. 1996;11(5):697-707. Exclude: Non-randomized head-to-head.
Ansari H, Patankar T, Jackson A. Whispering enigma. Br J Radiol. 2005;78(927):283-4. Exclude: Case study or series. [pmid: 15730998].
Anttonen H, Hassi J, Riihikangas P, et al. Impulse noise exposure during military service. Scand Audiol Suppl. 1980;(Suppl 12):17-24. Exclude: Only about prevalence. [pmid: 6939085].
Aran JM, Cazals Y. Electrical suppression of tinnitus. Ciba Foundation Symposium. 1981;85:217-31. Exclude: Case study or series. [pmid: 6976888].
Aran JM. Electrical stimulation of the auditory system and tinnitus control. J Laryngol Otol Suppl. 1981;(4):153-61. Exclude: Case study or series. [pmid: 6975341].
Araujo MF, Oliveira CA, Bahmad FM Jr. Intratympanic dexamethasone injections as a treatment for severe, disabling tinnitus: Does it work?. Arch Otolaryngol Head Neck Surg. 2005;131(2):113-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15723941].
Ariizumi Y, Hatanaka A, Kitamura K. Clinical prognostic factors for tinnitus retraining therapy with a sound generator in tinnitus patients. J Med Dent Sci. 2010;57(1):45-53. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20437765].
Arndt S, Aschendorff A, Laszig R, et al. Comparison of pseudobinaural hearing to real binaural hearing rehabilitation after cochlear implantation in patients with unilateral deafness and tinnitus. Otol Neurotol. 2011;32(1):39-47. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21068690].
Atlas J, Parnes LS. Intratympanic gentamicin for intractable Meniere’s disease: 5-year follow-up. J Otolaryngol. 2003;32(5):288-93. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 14974857].
Atlas JT, Parnes LS. Intratympanic gentamicin titration therapy for intractable Meniere’s disease. Am J Otol. 1999;20(3):357-63. Exclude: Tinnitus is somatic. [pmid: 10337978].
Attias J, Shemesh Z, Shoham C, et al. Efficacy of self-hypnosis for tinnitus relief. Scand Audiol. 1990;19(4):245-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2075417].
Attias J, Shemesh Z, Sohmer H, et al. Comparison between self-hypnosis, masking and attentiveness for alleviation of chronic tinnitus. Audiology. 1993;32(3):205-12. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8489481].
Axelsson A, Andersson S, Gu LD. Acupuncture in the management of tinnitus: A placebo-controlled study. Audiology. 1994;33(6):351-60. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7741667].
Ayache D, Earally F, Elbaz P. Characteristics and postoperative course of tinnitus in otosclerosis. Otol Neurotol. 2003;24(1):48-51. Exclude: Non-randomized head-to-head. [pmid: 12544028].
Aydemir G, Tezer MS, Borman P, et al. Treatment of tinnitus with transcutaneous electrical nerve stimulation improves patients’ quality of life. J Laryngol Otol. 2006;120(6):442-5. Exclude: Non-randomized head-to-head. [pmid: 16556347].
Baguley D. Neurophysiological approach to tinnitus patients. Am J Otol. 1997;18(2):265-6. Exclude: Not a primary study. [pmid: 9093687].
Baguley DM, Humphriss RL, Hodgson CA. Convergent validity of the tinnitus handicap inventory and the tinnitus questionnaire. J Laryngol Otol. 2000;114(11):840-3. Exclude: Non-randomized head-to-head. [pmid: 11144832].
Baguley DM, McFerran DJ. Current perspectives on tinnitus. Arch Dis Child. 2002;86(3):141-3. Exclude: Not a primary study. [pmid: 11861225].
Bahmad FM Jr, Venosa AR, Oliveira CA. Benzodiazepines and GABAergics in treating severe disabling tinnitus of predominantly cochlear origin. Int Tinnitus J. 2006;12(2):140-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17260879].
Bakhshaee M, Ghasemi M, Azarpazhooh M, et al. Gabapentin effectiveness on the sensation of subjective idiopathic tinnitus: A pilot study. Eur Arch Otorhinolaryngol. 2008;265(5):525-30. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17960408].
Baracca GN, Forti S, Crocetti A, et al. Results of TRT after eighteen months: Our experience. Int J Audiol. 2007;46(5):217-22. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17487669].
Barber HO. The diagnosis and treatment of auditory and vestibular disorders after head injury. Clin Neurosurg. 1972;19:355-70. Exclude: Not a primary study. [pmid: 4637559].
Baribeau J. Reaching out to the youth suffering from idiopathic tinnitus via the Internet. Ann Rev Cyberther Telemed. 2006;4:145-52. Exclude: Non-randomized head-to-head.
Barrs DM, Brackmann DE. Section 3: Surgical treatment. Translabyrinthine nerve section: Effect on tinnitus. J Laryngol Otol. 1983;97(Suppl 9):287-93. Exclude: Insufficient detail of outcome data/not extractable.
Bartels H, Middel B, Pedersen SS, et al. The distressed (Type D) personality is independently associated with tinnitus: A case-control study. Psychosomatics. 2010;51(1):29-38. Exclude: Non-randomized head-to-head. [pmid: 20118438].
Bartels H, Pedersen SS, van der Laan BF, et al. The impact of Type D personality on health-related quality of life in tinnitus patients is mainly mediated by anxiety and depression. Otol Neurotol. 2010;31(1):11-8. Exclude: Only determined various effects. [pmid: 19816233].
Bartels H, Staal MJ, Holm AF, et al. Long-term evaluation of treatment of chronic, therapeutically refractory tinnitus by neurostimulation. Stereotact Funct Neurosurg. 2007;85(4):150-7. Exclude: Case study or series. [pmid: 17259751].
Bartnik G, Fabijanska A, Rogowski M. Effects of tinnitus retraining therapy (TRT) for patients with tinnitus and subjective hearing loss versus tinnitus only. Scand Audiol Suppl. 2001;52:206-8. Exclude: Non-randomized head-to-head. [pmid: 11318470].
Bartnik G, Fabijanska A, Rogowski M. Experiences in the treatment of patients with tinnitus and/or hyperacusis using the habituation method. Scand Audiol Suppl. 2001;52:187-90. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 11318464].
Bauer CA, Brozoski TJ. Effect of gabapentin on the sensation and impact of tinnitus. Laryngoscope. 2006;116(5):675-81. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16652071].
Bauer CA, Brozoski TJ. Effect of tinnitus retraining therapy on the loudness and annoyance of tinnitus: A controlled trial. Ear Hear. 2011;32(2):145-55. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20890204].
Bauer W. Transcutaneous electrical stimulation. Arch Otolaryngol Head Neck Surg. 1986;112(12):1301-2. Exclude: Not a primary study. [pmid: 3490266].
Bayazit Y. Neurovascular decompression for tinnitus. J Neurosurg. 1998;89(6):1072-3. Exclude: Not a primary study. [pmid: 9833843].
Bayazit YA, Goksu N. Tinnitus and neurovascular compression. ORL. 2008;70(3):209. Exclude: Not a primary study. [pmid: 18401197].
Belli S, Belli H, Bahcebasi T, et al. Assessment of psychopathological aspects and psychiatric comorbidities in patients affected by tinnitus. Eur Arch Otorhinolaryngol. 2008;265(3):279-85. Exclude: Only determined various effects. [pmid: 17999075].
Bentler RA, Tyler RS. Tinnitus management. ASHA. 1987;29(5):27-32. Exclude: Article not available. [pmid: 3593456].
Bentzen O. Treatment of tinnitus with alternative therapy. Acta Otorhinolaryngol Belgica. 1986;40(3):487-91. Exclude: Not a primary study. [pmid: 3788551].
Berninger E, Nordmark J, Alvan G, et al. The effect of intravenously administered mexiletine on tinnitus - A pilot study. Int J Audiol. 2006;45(12):689-96. Exclude: Case study or series. [pmid: 17132557].
Berrios GE, Ryley JP, Garvey TPN, et al. Psychiatric morbidity in subjects with inner ear disease. Clin Otolaryngol Allied Sci. 1988;13(4):259-66. Exclude: Only determined various effects. [pmid: 3180496].
Berry JA, Gold SL, Frederick EA, et al. Patient-based outcomes in patients with primary tinnitus undergoing tinnitus retraining therapy. Arch Otolaryngol Head Neck Surg. 2002;128(10):1153-7. Exclude: Case study or series. [pmid: 12365886].
Bessman P, Heider T, Watten VP, et al. The tinnitus intensive therapy habituation program: A 2-year follow-up pilot study on subjective tinnitus. Rehabil Psychol. 2009;54(2):133-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19469602].
Bezerra Rocha CA, Sanchez TG, Tesseroli de Siqueira JT. Myofascial trigger point: A possible way of modulating tinnitus. Audiol Neuro Otol. 2008;13(3):153-60. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18075244].
Bjorne A. Assessment of temporomandibular and cervical spine disorders in tinnitus patients. Progr Brain Res. 2007;166:215-9. Exclude: Not a primary study. [pmid: 17956785].
Blair PA, Reed HT. Amino-oxyacetic acid: A new drug for the treatment of tinnitus. J La State Med Soc. 1986;138(6):17-9. Exclude: Not a primary study. [pmid: 3734755].
Blayney AW, Phillips MS, Guy AM, et al. A sequential double blind cross-over trial of tocainide hydrochloride in tinnitus. Clin Otolaryngol Allied Sci. 1985;10(2):97-101. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3928215].
Borghi C, Brandolini C, Prandin MG, et al. Prevalence of tinnitus in patients with hypertension and the impact of different antihypertensive drugs on the incidence of tinnitus: A prospective, single-blind, observational study. Curr Ther Res. 2005;66(5):420-32. Exclude: Only about prevalence.
Borton TE, Clark SR. Electromyographic biofeedback for treatment of tinnitus. Am J Otol. 1988;9(1):23-30. Exclude: Case study or series. [pmid: 3364533].
Bovo R, Ciorba A, Martini A. Tinnitus and cochlear implants. Auris Nasus Larynx. 2011;38(1):14-20. Exclude: Case study or series. [pmid: 20580171].
Bradley WD. Management of tinnitus. Cranio. 1989;7(2):75. Exclude: Not a primary study.
Briner W, House J, O’Leary M. Synthetic prostaglandin E1 misoprostol as a treatment for tinnitus. Arch Otolaryngol Head Neck Surg. 1993;119(6):652-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8499097].
Brookes GB. Vascular-decompression surgery for severe tinnitus. Am J Otol. 1996;17(4):569-76. Exclude: Case study or series. [pmid: 8841702].
Brookler KH, Tanyeri H. Etidronate for the neurotologic symptoms of otosclerosis: Preliminary study. Ear Nose Throat J. 1997;76(6):371-81. Exclude: Tinnitus is somatic. [pmid: 9210803].
Buechner A, Brendel M, Lesinski-Schiedat A, et al. Cochlear implantation in unilateral deaf subjects associated with ipsilateral tinnitus. Otol Neurotol. 2010;31(9):1381-5. Exclude: Case study or series. [pmid: 20729788].
Bumby AF, Stephens SDG. Clonazepam in the treatment of tinnitus - A pilot study. J Audiol Med. 1997;6(2):98-104. Exclude: Insufficient detail of outcome data/not extractable.
Burgos I, Feige B, Hornyak M, et al. Chronic tinnitus and associated sleep disturbances. Somnologie. 2005;9(3):133-8. Exclude: Only determined various effects.
Busis SN. Treatment of tinnitus. JAMA. 1992;268(11):1467. Exclude: Not a primary study. [pmid: 1512918].
Cada DJ, Baker DE, Levien T. Gatifloxacin. Hosp Pharm. 2000;35(4):405-17. Exclude: Article not available.
Caffier PP, Haupt H, Scherer H, et al. Outcomes of long-term outpatient tinnitus-coping therapy: Psychometric changes and value of tinnitus-control instruments. Ear Hear. 2006;27(6):619-27. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17086074].
Caffier PP, Sedlmaier B, Haupt H, et al. Impact of laser eustachian tuboplasty on middle ear ventilation, hearing, and tinnitus in chronic tube dysfunction. Ear Hear. 2011;32(1):132-9. Exclude: Non-randomized head-to-head. [pmid: 20585250].
Campbell K. Tinnitus and vertigo. Arch Otolaryngol Head Neck Surg. 1993;119(4):474. Exclude: Not a primary study. [pmid: 8457316].
Canis M, Olzowy B, Welz C, et al. Simvastatin and Ginkgo biloba in the treatment of subacute tinnitus: A retrospective study of 94 patients. Am J Otolaryngol. 2011;32(1):19-23. Exclude: Non-randomized head-to-head. [pmid: 20015810].
Canlon B, Henderson D, Salvi R. Pharmacological strategies for prevention and treatment of hearing loss and tinnitus. Hear Res. 2007;226(1–2):1-2. Exclude: Not a primary study. [pmid: 18379637].
Carbary LJ. Tuning out tinnitus. J Nurs Care. 1980;13(8):8-11. Exclude: Not a primary study. [pmid: 6904524].
Carlsson SG, Erlandsson SI. Habituation and tinnitus: An experimental study. J Psychosom Res. 1991;35(4–5):509-14. Exclude: Only determined various effects. [pmid: 1920181].
Carmen R, Svihovec D. Relaxation-biofeedback in the treatment of tinnitus. Am J Otol. 1984;5(5):376-81. Exclude: Case study or series. [pmid: 6383065].
Caro AZ. Dimethyl sulfoxide therapy in subjective tinnitus of unknown origin. Ann New York Acad Sci. 1975;243:468-74. Exclude: Case study or series. [pmid: 1055561].
Carrick DG, Davies WM, Fielder CP, et al. Low-powered ultrasound in the treatment of tinnitus: A pilot study. Br J Audiol. 1986;20(2):153-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3719163].
Catalano GB, Di Mauro A, Vancheri M. Tinnitus: Analysis of failures with Vernon treatment. Rivista Italiana di Otorinolaringologia Audiologia e Foniatria. 1982;2(1):60-2. Exclude: Article not available.
Cathcart JM. Assessment of the value of tocainide hydrochloride in the treatment of tinnitus. J Laryngol Otol. 1982;96(11):981-4. Exclude: Case study or series. [pmid: 6813410].
Cazals Y, Negrevergne M, Aran JM. Electrical stimulation of the cochlea in man: Hearing induction and tinnitus suppression. J Am Audiol Soc. 1978;3(5):209-13. Exclude: Case study or series. [pmid: 306987].
Cesarani A, Capobianco S, Soi D, et al. Intratympanic dexamethasone treatment for control of subjective idiopathic tinnitus: Our clinical experience. Int Tinnitus J. 2002;8(2):111-4. Exclude: Case study or series. [pmid: 14763222].
Chole RA, Parker WS. Tinnitus and vertigo in patients with temporomandibular disorder. Arch Otolaryngol Head Neck Surg. 1992;118(8):817-21. Exclude: Not a primary study. [pmid: 1642833].
Chopra H, Munjal M, Khurana AS, et al. Comparative study of lignocaine instillation (2% and 4%) and hydrocortisone through ventilation tubes in subjective tinnitus. Indian J Otol. 2002;8(2):63-5. Exclude: Article not available.
Chouard CH, Meyer B, Maridat D. Transcutaneous electrotherapy for severe tinnitus. Acta Otolaryngol. 1981;91(5–6):415-22. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6973909].
Choy DS, Lipman RA, Tassi GP. Worldwide experience with sequential phase-shift sound cancellation treatment of predominant tone tinnitus. J Laryngol Otol. 2010;124(4):366-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20067647].
Christensen RC. Paroxetine in the treatment of tinnitus. Otolaryngol Head Neck Surg. 2001;125(4):436-8. Exclude: Not a primary study. [pmid: 11593197].
Claire LS, Stothart G, McKenna L, et al. Caffeine abstinence: An ineffective and potentially distressing tinnitus therapy. Int J Audiol. 2010;49(1):24-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20053154].
Claussen CF. Industrial medicine: The future for vertigo and tinnitus patients. Int Tinnitus J. 2004;10(1):87-90. Exclude: Not a primary study. [pmid: 15379357].
Coad C. Nutritional supplement for Meniere’s disease and tinnitus. Positive Health. 2008;(151):1. Exclude: Not a primary study.
Coles R, Bradley P, Donaldson I, et al. A trial of tinnitus therapy with ear-canal magnets. Clin Otolaryngol Allied Sci. 1991;16(4):371-2. Exclude: Non-randomized head-to-head. [pmid: 1934552].
Coles R. Trial of an extract of Ginkgo biloba (EGB) for tinnitus and hearing loss. Clin Otolaryngol Allied Sci. 1988;13(6):501-2. Exclude: Not a primary study. [pmid: 3228994].
Coles RR, Baskill JL, Sheldrake JB. Measurement and management of tinnitus. Part II. Management. J Laryngol Otol. 1985;99(1):1-10. Exclude: Not a primary study. [pmid: 2578535].
Coles RR, Hallam RS. Tinnitus and its management. Br Med Bull. 1987;43(4):983-98. Exclude: Not a primary study. [pmid: 3329937].
Coles RR, Thompson AC, O’Donoghue GM. Intra-tympanic injections in the treatment of tinnitus. Clin Otolaryngol Allied Sci. 1992;17(3):240-2. Exclude: Case study or series. [pmid: 1505091].
Collet L, Moussu MF, Dubreuil C, et al. Psychological factors affecting outcome of treatment after transcutaneous electrotherapy for persistent tinnitus. Arch Oto-Rhino-Laryngol. 1987;244(1):20-2. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3497623].
Coping with tinnitus. ASHA. 1990;32(5):61. Exclude: Not a primary study. [pmid: 2337425].
Crocetti A, Forti S, Del BL. Neurofeedback for subjective tinnitus patients. Auris Nasus Larynx. 2011;38(6):735-8. Exclude: Non-randomized head-to-head. [pmid: 21592701].
Cronlein T, Langguth B, Geisler P, et al. Tinnitus and insomnia. Progr Brain Res. 2007;166:227-33. Exclude: Only determined various effects. [pmid: 17956787].
Cummings M, Lundeberg T. Acupuncture for tinnitus. Complement Ther Med. 2006;14(4):290-1. Exclude: Not a primary study. [pmid: 17105701].
Daneshi A, Mahmoudian S, Farhadi M, et al. Auditory electrical tinnitus suppression in patients with and without implants. Int Tinnitus J. 2005;11(1):85-91. Exclude: Non-randomized head-to-head. [pmid: 16419698].
Daneshmend TK. Treatment of tinnitus. BMJ. 1979;1(6178):1628. Exclude: Not a primary study. [pmid: 466159].
Dauman R, Tyler RS. Tinnitus suppression in cochlear implant users. Adv Otorhinolaryngol. 1993;48:168-73. Exclude: Case study or series. [pmid: 8273472].
David J, Naftali A, Katz A. Tinntrain: A multifactorial treatment for tinnitus using binaural beats. Hear J. 2010;63(11):25. Exclude: Not a primary study.
Davies E, Donaldson I. Tinnitus, membrane stabilizers and taurine. Practitioner. 1988;232(1456:(Pt 2)):1139. Exclude: Not a primary study. [pmid: 3256861].
Davies E, Knox E, Donaldson I. The usefulness of nimodipine, an L-calcium channel antagonist, in the treatment of tinnitus. Br J Audiol. 1994;28(3):125-9. Exclude: Case study or series. [pmid: 7841896].
Davies E. The pharmacological management of tinnitus. Audiol Med. 2004;2(1):26-8. Exclude: Not a primary study.
Davies S, McKenna L, Hallam RS. Relaxation and cognitive therapy: A controlled trial in chronic tinnitus. Psychol Health. 1995;10(2):129-43. Exclude: Non-randomized head-to-head.
Davis PB, Wilde RA, Steed LG, et al. Treatment of tinnitus with a customized acoustic neural stimulus: A controlled clinical study. Ear Nose Throat J. 2008;87(6):330-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18561116].
Dawes PJ, Welch D. Childhood hearing and its relationship with tinnitus at thirty-two years of age. Ann Otol Rhinol Laryngol. 2010;119(10):672-6. Exclude: Only about prevalence. [pmid: 21049852].
de Azevedo AA, Langguth B, de Oliveira PM, et al. Tinnitus treatment with piribedil guided by electrocochleography and acoustic otoemissions. Otol Neurotol. 2009;30(5):676-80. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19574947].
de Azevedo RF, Chiari BM, Okada DM, et al. Impact of acupuncture on otoacoustic emissions in patients with tinnitus. Revista Brasileira de Otorrinolaringologia. 2007;73(5):599-607. Exclude: Non-randomized head-to-head. [pmid: 18094800].
De Ridder D, Vanneste S, Kovacs S, et al. Transcranial magnetic stimulation and extradural electrodes implanted on secondary auditory cortex for tinnitus suppression. J Neurosurg. 2011;114(4):903-11. Exclude: Case study or series. [pmid: 21235318].
De Ridder D, De Mulder G, Menovsky T, et al. Electrical stimulation of auditory and somatosensory cortices for treatment of tinnitus and pain. Progr Brain Res. 2007;166:377-88. Exclude: Case study or series. [pmid: 17956802].
De Ridder D, Menovsky T, Van de Heyning P. Auditory cortex stimulation for tinnitus suppression. Otol Neurotol. 2008;29(4):574-5. Exclude: Not a primary study. [pmid: 18418286].
De Ridder D, Vanneste S, Adriaenssens I, et al. Microvascular decompression for tinnitus: Significant improvement for tinnitus intensity without improvement for distress. A 4-year limit. Neurosurg. 2010;66(4):656-60. Exclude: Case study or series. [pmid: 20305490].
De Ridder D, Vanneste S, van der Loo E, et al. Burst stimulation of the auditory cortex: A new form of neurostimulation for noise-like tinnitus suppression. J Neurosurg. 2010;112(6):1289-94. Exclude: Case study or series. [pmid: 19911891].
De Ridder D, Verstraeten E, Van der Kelen K, et al. Transcranial magnetic stimulation for tinnitus: Influence of tinnitus duration on stimulation parameter choice and maximal tinnitus suppression. Otol Neurotol. 2005;26(4):616-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16015156].
De Valck C, Van Rompaey V, Wuyts FL, et al. Tenotomy of the tensor tympani and stapedius tendons in Meniere’s disease. B-ENT. 2009;5(1):1-6. Exclude: Tinnitus is somatic. [pmid: 19455992].
DeBartolo HM Jr. Zinc and diet for tinnitus. Am J Otol. 1989;10(3):256. Exclude: Not a primary study. [pmid: 2750874].
DeBisschop M. Ginkgo ineffective for tinnitus. J Fam Pract. 2003;52(10):766. Exclude: Not a primary study. [pmid: 14529599].
DeCicco MJ, Hoffer ME, Kopke RD, et al. Round-Window Microcatheter-administered microdose gentamicin: Results from treatment of tinnitus associated with Meniere’s disease. Int Tinnitus J. 1998;4(2):141-3. Exclude: Case study or series. [pmid: 10753403].
Dehler R, Dehler F, Claussen CF, et al. Competitive-kinesthetic interaction therapy. Int Tinnitus J. 2000;6(1):29-35. Exclude: Case study or series. [pmid: 14689615].
Dejonckere PH, Coryn C, Lebacq J. Experience with a medicolegal decision-making system for occupational hearing loss-related tinnitus. Int Tinnitus J. 2009;15(2):185-92. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20420345].
DeLucchi E. Transtympanic pilocarpine in tinnitus. Int Tinnitus J. 2000;6(1):37-40. Exclude: Case study or series. [pmid: 14689616].
Demajumdar R, Stoddart R, Donaldson I, et al. Tinnitus, cochlear implants and how they affect patients. J Laryngol Otol Suppl. 1999;24:24-6. Exclude: Non-randomized head-to-head. [pmid: 10664726].
den Hartigh J, Hilders CG, Schoemaker RC, et al. Tinnitus suppression by intravenous lidocaine in relation to its plasma concentration. Clin Pharmacol Therapeut. 1993;54(4):415-20. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8222484].
Denk DM, Heinzl H, Franz P, et al. Caroverine in tinnitus treatment. A placebo-controlled blind study. Acta Otolaryngol. 1997;117(6):825-30. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9442821].
Densert B, Densert O, Arlinger S, et al. Immediate effects of middle ear pressure changes on the electrocochleographic recordings in patients with Meniere’s disease: A clinical placebo-controlled study. Am J Otol. 1997;18(6):726-33. Exclude: Tinnitus is somatic. [pmid: 9391668].
Di Nardo W, Cantore I, Cianfrone F, et al. Tinnitus modifications after cochlear implantation. Eur Arch Otorhinolaryngol. 2007;264(10):1145-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17558507].
Di Nardo W, Cianfrone F, Scorpecci A, et al. Transtympanic electrical stimulation for immediate and long-term tinnitus suppression. Int Tinnitus J. 2009;15(1):100-6. Exclude: Case study or series. [pmid: 19842353].
Dias A, Cordeiro R. Association between hearing loss level and degree of discomfort introduced by tinnitus in workers exposed to noise. Revista Brasileira de Otorrinolaringologia. 2008;74(6):876-83. Exclude: Non-randomized head-to-head. [pmid: 19582344].
Dibb B, Yardley L. How does social comparison within a self-help group influence adjustment to chronic illness? A longitudinal study. Soc Sci Med. 2006;63(6):1602-13. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16716478].
Dickter AE, Durrant JD, Ronis ML. Correlation of the complaint of tinnitus with central auditory testing. J Laryngol Otol Suppl. 1981;(4):52-9. Exclude: Case study or series. [pmid: 6946171].
Dobie RA, Hoberg KE, Rees TS. Electrical tinnitus suppression: A double-blind crossover study. Otolaryngol Head Neck Surg. 1986;95(3:Pt 1):319-23. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3108780].
Dobie RA, Sakai CS. Frusemide open trial for treatment of tinnitus. J Audiol Med. 1993;2(3):167-74. Exclude: Insufficient detail of outcome data/not extractable.
Dobie RA, Sullivan MD, Katon WJ, et al. Antidepressant treatment of tinnitus patients. Interim report of a randomized clinical trial. Acta Otolaryngol. 1992;112(2):242-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 1604987].
Dobie RA. Patients with tinnitus may benefit from antidepressant therapy. Am Fam Physician. 1992;46(1):241. Exclude: Not a primary study.
Domeisen H, Hotz MA, Hausler R. Caroverine in tinnitus treatment. Acta Otolaryngol. 1998;118(4):606-8. Exclude: Not a primary study. [pmid: 9726691].
Domenech J, Cuchi MA, Carulla M. High-frequency hearing loss in patients with tinnitus. Adv Otorhinolaryngol. 1990;45:203-5. Exclude: Non-randomized head-to-head. [pmid: 2077891].
Donaldson I. Tinnitus: A theoretical view and a therapeutic study using amylobarbitone. J Laryngol Otol. 1978;92(2):123-30. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 627765].
Dong CH. Clinical observation of acupuncture on nervous tinnitus and deafness. Int J Clin Acupuncture. 1996;7(4):469-71. Exclude: Case study or series.
Dong-Kee K, Shi-Nae P, Hyung Min K, et al. Prevalence and significance of high-frequency hearing loss in subjectively normal-hearing patients with tinnitus. Ann Otol Rhinol Laryngol. 2011;120(8):523-8. Exclude: Only about prevalence. [pmid: 21922976].
Dornhoffer JL, Mennemeier M. Transcranial magnetic stimulation and tinnitus: Implications for theory and practice. J Neurol Neurosurg Psychiatry. 2010;81(12):1414. Exclude: Not a primary study.
Dornhoffer JL, Mennemeier M. Transcranial magnetic stimulation and tinnitus: Implications for theory and practice. J Neurol Neurosurg Psychiatry. 2010;81(1):126. Exclude: Not a primary study.
Duckert LG, Rees TS. Placebo effect in tinnitus management. Otolaryngol Head Neck Surg. 1984;92(6):697-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6440090].
Duckert LG, Rees TS. Treatment of tinnitus with intravenous lidocaine: A double-blind randomized trial. Otolaryngol Head Neck Surg. 1983;91(5):550-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6417606].
Dyczek H. Tinnitus helped by chiropractic. Int J Alternat Complement Med. 1995;13(5):12. Exclude: Not a primary study.
Ehrenberger K. Topical administration of Caroverine in somatic tinnitus treatment: Proof-of-concept study. Int Tinnitus J. 2005;11(1):34-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16419686].
Eklund S, Pyykko I, Aalto H, et al. Effect of intratympanic gentamicin on hearing and tinnitus in Meniere’s disease. Am J Otol. 1999;20(3):350-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10337977].
El Refaie A, Davis A, Kayan A, et al. A questionnaire study of the quality of life and quality of family life of individuals complaining of tinnitus pre- and post-attendance at a tinnitus clinic. Int J Audiol. 2004;43(7):410-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15515640].
Electrical stimulation of the inner ear. J Laryngol Otol Suppl. 1984;9:121-44. Exclude: Article not available. [pmid: 6394678].
Emmett JR, Shea JJ. Medical treatment of tinnitus. J Laryngol Otol. 1983;97(Suppl 9):264-70. Exclude: Insufficient detail of outcome data/not extractable.
Emmett JR, Shea JJ. Treatment of tinnitus aurium with Tocainide HCl. Otolaryngol Head Neck Surg. 1979;87(4 II):196-7. Exclude: Not a primary study.
Emmett JR, Shea JJ. Treatment of tinnitus with tocainide hydrochloride. Otolaryngol Head Neck Surg. 1980;88(4):442-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6821429].
Engelberg M, Bauer W. Transcutaneous electrical stimulation for tinnitus. Laryngoscope. 1985;95(10):1167-73. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3900611].
Erlandsson S, Ringdahl A, Hutchins T, et al. Treatment of tinnitus: A controlled comparison of masking and placebo. Br J Audiol. 1987;21(1):37-44. Exclude: Non-randomized head-to-head. [pmid: 3828583].
Evans DL, Golden RN. Protriptyline and tinnitus. J Clin Psychopharmacol. 1981;1(6):404-6. Exclude: Case study or series. [pmid: 7334152].
Evans RW, Ishiyama G. Migraine with transient unilateral hearing loss and tinnitus. Headache. 2009;49(5):756-8. Exclude: Case study or series. [pmid: 19472451].
Falkenberg E-S, Tungland OP, Skollerud S. Habituation therapy of chronic distressing tinnitus: A presentation of a treatment programme and an evaluation study of its effects. Audiol Med. 2003;1(2):132-7. Exclude: Non-randomized head-to-head.
Farace E, Marshall LF, Betchen SA, et al. Quality of life in acoustics. J Neurosurg. 2003;99(5):807-9. Exclude: Not a primary study. [pmid: 14609157].
Fattori B, De Iaco G, Nacci A, et al. Alternobaric oxygen therapy in long-term treatment of Meniere’s disease. Undersea Hyperb Med. 2002;29(4):260-70. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 12797667].
Fattori B, De IG, Vannucci G, et al. Alternobaric and hyperbaric oxygen therapy in the immediate and long-term treatment of Meniere’s disease. Audiology. 1996;35(6):322-34. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9018366].
Feldmann H. Homolateral and contralateral masking of tinnitus by noise-bands and by pure tones. Audiology. 1971;10(3):138-44. Exclude: Not a primary study. [pmid: 5163656].
Feldmann H. Homolateral and contralateral masking of tinnitus. J Laryngol Otol Suppl. 1981;(4):60-70. Exclude: Not a primary study. [pmid: 6946172].
Figueiredo RR, Azevedo AA, Oliveira PM. Correlation analysis of the visual-analogue scale and the Tinnitus Handicap Inventory in tinnitus patients. Revista Brasileira de Otorrinolaringologia. 2009;75(1):76-9. Exclude: Non-randomized head-to-head. [pmid: 19488564].
Figueiredo RR, Rates MA, Azevedo AA, et al. Correlation analysis of hearing thresholds, validated questionnaires and psychoacoustic measurements in tinnitus patients. Revista Brasileira de Otorrinolaringologia. 2010;76(4):522-6. Exclude: Non-randomized head-to-head. [pmid: 20835541].
Flor H, Hoffmann D, Struve M, et al. Auditory discrimination training for the treatment of tinnitus. Appl Psychophysiol Biofeedback. 2004;29(2):113-20. Exclude: Case study or series. [pmid: 15208974].
Folmer RL, Carroll JR, Rahim A, et al. Effects of repetitive transcranial magnetic stimulation (rTMS) on chronic tinnitus. Acta Otolaryngol Suppl. 2006;(556):96-101. Exclude: Case study or series. [pmid: 17114152].
Folmer RL, Carroll JR. Long-term effectiveness of ear-level devices for tinnitus. Otolaryngol Head Neck Surg. 2006;134(1):132-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16399193].
Folmer RL, Griest SE, Martin WH. Chronic tinnitus as phantom auditory pain. Otolaryngol Head Neck Surg. 2001;124(4):394-400. Exclude: Only determined various effects. [pmid: 11283496].
Folmer RL, Griest SE. Tinnitus and insomnia. Am J Otolaryngol. 2000;21(5):287-93. Exclude: Only determined various effects. [pmid: 11032291].
Folmer RL, Shi YB. SSRI use by tinnitus patients: Interactions between depression and tinnitus severity. Ear Nose Throat J. 110;83(2):107-8. Exclude: Non-randomized head-to-head. [pmid: 15008444].
Folmer RL. Long-term reductions in tinnitus severity. BMC Ear Nose Throat Disord. 2002;2:1-9. Exclude: Non-randomized head-to-head. [pmid: 11964189].
Folmer RL. Repetitive transcranial magnetic stimulation for tinnitus. Arch Otolaryngol Head Neck Surg. 2011;137(7):730. Exclude: Not a primary study. [pmid: 21768426].
Folmer RL. Transcranial magnetic stimulation for tinnitus. Otol Neurotol. 2005;26(6):1262-3. Exclude: Not a primary study. [pmid: 16272954].
Formby C, Gold SL, Keaser ML, et al. Secondary benefits from tinnitus retraining therapy: Clinically significant increases in loudness discomfort level and expansion of the auditory dynamic range. Semin Hear. 2007;28(4):227-60. Exclude: Non-randomized head-to-head.
Formby C, Keaser ML. Secondary treatment benefits achieved by hearing-impaired tinnitus patients using aided environmental sound therapy for tinnitus retraining therapy: Comparisons with matched groups of tinnitus patients using noise generators for sound therapy. Semin Hear. 2007;28(4):276-94. Exclude: Insufficient detail of outcome data/not extractable.
Forti S, Costanzo S, Crocetti A, et al. Are results of tinnitus retraining therapy maintained over time? 18-month follow-up after completion of therapy. Audiol Neuro Otol. 2009;14(5):286-9. Exclude: Non-randomized head-to-head. [pmid: 19372645].
Forti S, Crocetti A, Scotti A, et al. Tinnitus sound therapy with open ear canal hearing aids. B-ENT. 2010;6(3):195-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21090162].
Fortnum HM, Coles RR. Trial of flecainide acetate in the management of tinnitus. Clin Otolaryngol Allied Sci. 1991;16(1):93-6. Exclude: Case study or series. [pmid: 1903336].
Fradis M, Podoshin L, Ben-David J, et al. Treatment of Meniere’s disease by intratympanic injection with lidocaine. Arch Otolaryngol. 1985;111(8):491-3. Exclude: Tinnitus is somatic. [pmid: 4026655].
Frank E, Landgrebe M, Kleinjung T, et al. Burst transcranial magnetic stimulation for the treatment of tinnitus. CNS Spect. 2010;15(8):536-7. Exclude: Not a primary study.
Frank G, Kleinjung T, Landgrebe M, et al. Left temporal low-frequency rTMS for the treatment of tinnitus: Clinical predictors of treatment outcome--a retrospective study. Eur J Neurol. 2010;17(7):951-6. Exclude: Non-randomized head-to-head. [pmid: 20158510].
Frankenburg FR, Hegarty JD. Tinnitus, psychosis, and suicide. Arch Intern Med. 1994;154(20):2371. Exclude: Not a primary study. [pmid: 7944860].
Franz B, Collis-Brown G, Altidis P, et al. Cervical trauma and tinnitus. Int Tinnitus J. 1998;4(1):31-3. Exclude: Case study or series. [pmid: 10753382].
Franz B, Offutt G. Tinnitus suppression with threshold and subthreshold sound stimuli. Int Tinnitus J. 2003;9(1):11-6. Exclude: Case study or series. [pmid: 14763323].
Fregni F, Marcondes R, Boggio PS, et al. Transient tinnitus suppression induced by repetitive transcranial magnetic stimulation and transcranial direct current stimulation. Eur J Neurol. 2006;13(9):996-1001. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16930367].
Frew IJ, Menon GN. Betahistine hydrochloride in Meniere’s disease. Postgrad Med J. 1976;52(610):501-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 790351].
Friedland DR, Gaggl W, Runge-Samuelson C, et al. Feasibility of auditory cortical stimulation for the treatment of tinnitus. Otol Neurotol. 2007;28(8):1005-12. Exclude: Case study or series. [pmid: 18043428].
Fukuda S, Miyashita T, Inamoto R, et al. Tinnitus retraining therapy using portable music players. Auris Nasus Larynx. 2011;38(6):692-6. Exclude: Non-randomized head-to-head. [pmid: 21601395].
Gabr TA, El-Hay MA, Badawy A. Electrophysiological and psychological studies in tinnitus. Auris Nasus Larynx. 2011;38(6):678-83. Exclude: Only determined various effects. [pmid: 21371837].
Gananca MM, Caovilla HH, Gananca FF, et al. Clonazepam in the pharmacological treatment of vertigo and tinnitus. Int Tinnitus J. 2002;8(1):50-3. Exclude: Case study or series. [pmid: 14763236].
Garduno-Anaya MA, De Toledo HC, Hinojosa-Gonzalez R, et al. Dexamethasone inner ear perfusion by intratympanic injection in unilateral Meniere’s disease: A two-year prospective, placebo-controlled, double-blind, randomized trial. Otolaryngol Head Neck Surg. 2005;133(2):285-94. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16087029].
Garin P, Gilain C, Van Damme JP, et al. Short- and long-lasting tinnitus relief induced by transcranial direct current stimulation. Journal of Neurology. 2011;258(11):1940-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21509429].
Gavilan J, Gavilan C. Middle fossa vestibular neurectomy. Long-term results. Arch Otolaryngol. 1984;110(12):785-7. Exclude: Non-randomized head-to-head. [pmid: 6508626].
Gerber KE, Nehemkis AM, Charter RA, et al. Is tinnitus a psychological disorder?. Int J Psychiatr Med. 1985;15(1):81-7. Exclude: Article not available. [pmid: 4055250].
Gersdorff M, Nouwen J, Gilain C, et al. Tinnitus and otosclerosis. Eur Arch Otorhinolaryngol. 2000;257(6):314-6. Exclude: Case study or series. [pmid: 10993550].
Geven LI, de Kleine E, Free RH, et al. Contralateral suppression of otoacoustic emissions in tinnitus patients. Otol Neurotol. 2011;32(2):315-21. Exclude: Only determined various effects. [pmid: 20962699].
Giannasi LC, Almeida FR, Magini M, et al. Systematic assessment of the impact of oral appliance therapy on the temporomandibular joint during treatment of obstructive sleep apnea: Long-term evaluation. Sleep and Breathing. 2009;13(4):375-81. Exclude: Only about prevalence. [pmid: 19437057].
Ginsberg DL. Sertraline for severe tinnitus. Prim Psychiatr. 2006;13(3):32-3. Exclude: Not a primary study.
Giridharan W, Papanikolou V, Knight L. ‘Buzz’ in the ear. Ear Nose Throat J. 2004;83(2):83. Exclude: Case study or series. [pmid: 15008436].
Goddard JC, Berliner K, Luxford WM. Recent experience with the neuromonics tinnitus treatment. Int Tinnitus J. 2009;15(2):168-73. Exclude: Non-randomized head-to-head. [pmid: 20420343].
Goebel G, Kahl M, Arnold W, et al. 15-year prospective follow-up study of behavioral therapy in a large sample of inpatients with chronic tinnitus. Acta Otolaryngol Suppl. 2006;(556):70-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17114147].
Golden RN, Evans DL. Antidepressants and tinnitus. Arch Intern Med. 1994;154(12):1411. Exclude: Not a primary study. [pmid: 8002694].
Goldstein B, Shulman A, Avitable MJ. Clear Tinnitus, middle-ear pressure, and tinnitus relief: A prospective trial. Int Tinnitus J. 2007;13(1):29-39. Exclude: Tinnitus is somatic. [pmid: 17691660].
Goldstein BA, Lenhardt ML, Shulman A. Tinnitus improvement with ultra-high-frequency vibration therapy. Int Tinnitus J. 2005;11(1):14-22. Exclude: Non-randomized head-to-head. [pmid: 16419683].
Goldstein BA, Shulman A, Lenhardt ML, et al. Long-term inhibition of tinnitus by UltraQuiet therapy: Preliminary report. Int Tinnitus J. 2001;7(2):122-7. Exclude: Case study or series. [pmid: 14689651].
Goldstein BA, Shulman A, Lenhardt ML. Ultra-high-frequency ultrasonic external acoustic stimulation for tinnitus relief: A method for patient selection. Int Tinnitus J. 2005;11(2):111-4. Exclude: Non-randomized head-to-head. [pmid: 16639909].
Goldstein BA, Shulman A. Tinnitus outcome profile and tinnitus control. Int Tinnitus J. 2003;9(1):26-31. Exclude: Non-randomized head-to-head. [pmid: 14763326].
Goodwin PE, Johnson RM. The loudness of tinnitus. Acta Otolaryngol. 1980;90(5–6):353-9. Exclude: Case study or series. [pmid: 7211329].
Göörtelmeyer R, Schmidt J, Suckfüüll M, et al. Assessment of tinnitus-related impairments and disabilities using the German THI-12: Sensitivity and stability of the scale over time. Int J Audiol. 2011;50(8):523-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21751942].
Gopinath B, McMahon CM, Rochtchina E, et al. Incidence, persistence, and progression of tinnitus symptoms in older adults: The Blue Mountains Hearing Study. Ear Hear. 2010;31(3):407-12. Exclude: Only about prevalence. [pmid: 20124901].
Gopinath B, McMahon CM, Rochtchina E, et al. Risk factors and impacts of incident tinnitus in older adults. Ann Epidemiol. 2010;20(2):129-35. Exclude: Only determined various effects. [pmid: 20123163].
Gordon AG. Tinnitus and hallucinations. J Am Acad Child Adolesc Psychiatr. 1988;27(1):140-1. Exclude: Not a primary study. [pmid: 3343202].
Graham JM, Hazell JW. Electrical stimulation of the human cochlea using a transtympanic electrode. Br J Audiol. 1977;11(2):59-62. Exclude: Non-randomized head-to-head. [pmid: 922226].
Graham MD, Sataloff RT, Kemink JL. Tinnitus in Meniere’s disease: Response to titration streptomycin therapy. J Laryngol Otol. 1983;97(Suppl 9):281-6. Exclude: Case study or series.
Graul J, Klinger R, Greimel KV, et al. Differential outcome of a multimodal cognitive-behavioral inpatient treatment for patients with chronic decompensated tinnitus. Int Tinnitus J. 2008;14(1):73-81. Exclude: Non-randomized head-to-head. [pmid: 18616090].
Griffitts TM, Collins CP, Collins PC, et al. Walker repair of the temporomandibular joint: A retrospective evaluation of 117 patients. J Oral Maxillofac Surg. 2007;65(10):1958-62. Exclude: Case study or series. [pmid: 17884522].
Grossan M. Treatment of subjective tinnitus with biofeedback. Ear Nose Throat J. 1976;55(10):314-8. Exclude: Case study or series. [pmid: 991780].
Grossi MG, Belcaro G, Cesarone MR, et al. Improvement in cochlear flow with Pycnogenol® in patients with tinnitus: A pilot evaluation. Panminerva Medica. 2010;52(2:Suppl 1):63-7. Exclude: Non-randomized head-to-head. [pmid: 20657537].
Gudex C, Skellgaard PH, West T, et al. Effectiveness of a tinnitus management programme: A 2-year follow-up study. BMC Ear Nose Throat Disord. 2009;9(1):6. Exclude: Non-randomized head-to-head. [pmid: 19558680].
Gul H, Nowak R, Buchner FA, et al. Different treatment modalities of tinnitus at the EuromedClinic. Int Tinnitus J. 2000;6(1):50-3. Exclude: Case study or series. [pmid: 14689618].
Gurr P, Owen G, Reid A, et al. Tinnitus in pregnancy. Clin Otolaryngol Allied Sci. 1993;18(4):294-7. Exclude: Only about prevalence. [pmid: 8877189].
Guth PS, Risey J, Briner W, et al. Evaluation of amino-oxyacetic acid as a palliative in tinnitus. Ann Otol Rhinol Laryngol. 1990;99(1):74-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 1688487].
Haginomori S, Makimoto K, Araki M, et al. Effect of lidocaine injection of EOAE in patients with tinnitus. Acta Otolaryngol. 1995;115(4):488-92. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7572122].
Hahn A, Radkova L, Achiemere G, et al. Multimodal therapy for chronic tinnitus. Int Tinnitus J. 2008;14(1):69-72. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18616089].
Halford JB, Anderson SD. Anxiety and depression in tinnitus sufferers. J Psychosom Res. 1991;35(4–5):383-90. Exclude: Only determined various effects. [pmid: 1920169].
Halford JB, Anderson SD. Tinnitus severity measured by a subjective scale, audiometry and clinical judgement. J Laryngol Otol. 1991;105(2):89-93. Exclude: Non-randomized head-to-head. [pmid: 2013737].
Hallam RS, Jakes SC, Chambers C, et al. A comparison of different methods for assessing the ‘intensity’ of tinnitus. Acta Otolaryngol. 1985;99(5–6):501-8. Exclude: Non-randomized head-to-head. [pmid: 4024897].
Haller S, Birbaumer N, Veit R. Real-time fMRI feedback training may improve chronic tinnitus. Eur Radiol. 2010;20(3):696-703. Exclude: Case study or series. [pmid: 19760238].
Halmos P, Molnar L, Kormos M. Experiences made with anticonvulsiva in the therapy of tinnitus. HNO-Praxis. 1982;7(1):59-61. Exclude: Article not available.
Hammami B, Chakroun A, Achour I, et al. Transmission deafness and tinnitus: What diagnosis?. Eur Ann Otorhinolaryngol Head Neck Dis. 2010;127(5):193-6. Exclude: Case study or series. [pmid: 21035422].
Handscomb L. Analysis of responses to individual items on the tinnitus handicap inventory according to severity of tinnitus handicap. Am J Audiol. 2006;15(2):102-7. Exclude: Only determined various effects. [pmid: 17182874].
Handscomb L. Use of bedside sound generators by patients with tinnitus-related sleeping difficulty: Which sounds are preferred and why?. Acta Otolaryngol Suppl. 2006;(556):59-63. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17114145].
Hanley PJ, Davis PB, Paki B, et al. Treatment of tinnitus with a customized, dynamic acoustic neural stimulus: Clinical outcomes in general private practice. Ann Otol Rhinol Laryngol. 2008;117(11):791-9. Exclude: Non-randomized head-to-head. [pmid: 19102123].
Hann D, Searchfield GD, Sanders M, et al. Strategies for the selection of music in the short-term management of mild tinnitus. Aust NZ J Audiol. 2008;30(2):129-40. Exclude: Insufficient detail of outcome data/not extractable.
Hansen PE, Hansen JH, Bentzen O. Acupuncture treatment of chronic unilateral tinnitus--A double-blind cross-over trial. Clin Otolaryngol Allied Sci. 1982;7(5):325-9. Exclude: Non-randomized head-to-head. [pmid: 6756709].
Hansen PE, Hansen JH, Bentzen O. Acupuncture treatment of chronic unilateral tinnitus. A double-blind cross-over investigation. Ugeskr-Laeg. 1981;143(44):2888-90. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7034339].
Happich M, Moock J, von LT. Health state valuation methods and reference points: The case of tinnitus. Value Health. 2009;12(1):88-95. Exclude: Non-randomized head-to-head. [pmid: 19911443].
Haralambous G, Wilson PH, Platt-Hepworth S, et al. EMG biofeedback in the treatment of tinnitus: An experimental evaluation. Behav Res Ther. 1987;25(1):49-55. Exclude: Non-randomized head-to-head. [pmid: 3593161].
Harrop-Griffiths J, Katon W, Dobie R, et al. Chronic tinnitus: Association with psychiatric diagnoses. J Psychosom Res. 1987;31(5):613-21. Exclude: Only determined various effects. [pmid: 3430424].
Hastak SM. Treatment of memory impairment, vertigo and tinnitus in the elderly with piribedil in an Indian general practice setting. J Indian Med Assoc. 2003;101(8):500-1. Exclude: Case study or series. [pmid: 15071809].
Hatanaka A, Ariizumi Y, Kitamura K. Pros and cons of tinnitus retraining therapy. Acta Otolaryngol. 2008;128(4):365-8. Exclude: Non-randomized head-to-head. [pmid: 18368566].
Hawthorne M, O’Connor S. The psychological side of tinnitus. BMJ Clin Res Ed. 1987;294(6585):1441-2. Exclude: Not a primary study. [pmid: 3111582].
Hawthorne MR, Britten SR, O’Connor S, et al. The management of a population of tinnitus sufferers in a specialized clinic: Part III. The evaluation of psychiatric intervention. J Laryngol Otol. 1987;101(8):795-9. Exclude: Not a primary study. [pmid: 3655532].
Hayes R. On helping people with tinnitus to help themselves. Br J Audiol. 1987;21(4):327-8. Exclude: Not a primary study. [pmid: 3690071].
Hazell JW, Jastreboff PJ, Meerton LE, et al. Electrical tinnitus suppression: Frequency dependence of effects. Audiology. 1993;32(1):68-77. Exclude: Case study or series. [pmid: 8447763].
Hazell JW, McKinney CJ, Aleksy W. Mechanisms of tinnitus in profound deafness. Ann Otol Rhinol Laryngol Suppl. 1995;166:418-20. Exclude: Non-randomized head-to-head. [pmid: 7668731].
Hazell JW, Wood S. Tinnitus masking-A significant contribution to tinnitus management. Br J Audiol. 1981;15(4):223-30. Exclude: Not a primary study. [pmid: 7296101].
Hazell JW, Wood SM, Cooper HR, et al. A clinical study of tinnitus maskers. Br J Audiol. 1985;19(2):65-146. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3896355].
Hazell JW. Tinnitus. Practitioner. 1981;225(1361):1577-85. Exclude: Article not available. [pmid: 7335587].
Hazell JWP, Wood SM. Drug therapy and tinnitus: The UK experience. J Laryngol Otol. 1983;97(Suppl 9):277-80. Exclude: Not a primary study.
Hebert S, Carrier J. Sleep complaints in elderly tinnitus patients: A controlled study. Ear Hear. 2007;28(5):649-55. Exclude: Only determined various effects. [pmid: 17804979].
Hebert S, Fullum S, Carrier J. Polysomnographic and quantitative electroencephalographic correlates of subjective sleep complaints in chronic tinnitus. J Sleep Res. 2011;20(1:Pt 1):38-44. Exclude: Only determined various effects. [pmid: 20561177].
Hebert S, Lupien SJ. Salivary cortisol levels, subjective stress, and tinnitus intensity in tinnitus sufferers during noise exposure in the laboratory. Int J Hyg Environ Health. 2009;212(1):37-44. Exclude: Only determined various effects. [pmid: 18243788].
Henry JA, James KE, Owens K, et al. Auditory test result characteristics of subjects with and without tinnitus. J Rehab Res Dev. 2009;46(5):619-32. Exclude: Only determined various effects. [pmid: 19882495].
Henry JA, Rheinsburg B, Owens KK, et al. New instrumentation for automated tinnitus psychoacoustic assessment. Acta Otolaryngol Suppl. 2006;(556):34-8. Exclude: Non-randomized head-to-head. [pmid: 17114140].
Henry JA, Rheinsburg B, Zaugg T. Comparison of custom sounds for achieving tinnitus relief. J Am Acad Audiol. 2004;15(8):585-98. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15553658].
Henry JA, Schechter MA, Zaugg TL, et al. Clinical trial to compare tinnitus masking and tinnitus retraining therapy. Acta Otolaryngol Suppl. 2006;(556):64-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17114146].
Henry JA, Schechter MA, Zaugg TL, et al. Outcomes of clinical trial: Tinnitus masking versus tinnitus retraining therapy. J Am Acad Audiol. 2006;17(2):104-32. Exclude: Non-randomized head-to-head. [pmid: 16640064].
Henry JL, Kangas M, Wilson PH. Development of the psychological impact of tinnitus interview: A clinician-administered measure of tinnitus-related distress. Int Tinnitus J. 2001;7(1):20-6. Exclude: Non-randomized head-to-head. [pmid: 14964950].
Henry JL, Wilson PH. The psychometric properties of two measures of tinnitus complaint and handicap. Int Tinnitus J. 1998;4(2):114-21. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10753398].
Herraiz C, Diges I, Cobo P, et al. Auditory discrimination therapy (ADT) for tinnitus managment: Preliminary results. Acta Otolaryngol Suppl. 2006;(556):80-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17114148].
Herraiz C, Diges I, Cobo P. Auditory discrimination therapy (ADT) for tinnitus management. Progr Brain Res. 2007;166:467-71. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17956811].
Herraiz C, Hernandez FJ, Plaza G, et al. Long-term clinical trial of tinnitus retraining therapy. Otolaryngol Head Neck Surg. 2005;133(5):774-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16274808].
Herraiz C, Hernandez FJ, Toledano A, et al. Tinnitus retraining therapy: Prognosis factors. Am J Otolaryngol. 2007;28(4):225-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17606035].
Herraiz C, Plaza F, de los SG. Tinnitus retraining therapy in Meniere disease. Acta Otorrinolaringol Espanola. 2006;57(2):96-100. Exclude: Case study or series.
Herraiz C, Plaza G, Aparicio JM, et al. Transtympanic steroids for Meniere’s disease. Otol Neurotol. 2010;31(1):162-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19924013].
Herraiz C, Toledano A, Diges I. Trans-electrical nerve stimulation (TENS) for somatic tinnitus. Progr Brain Res. 2007;166:389-94. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17956803].
Hesser H, Andersson G. The role of anxiety sensitivity and behavioral avoidance in tinnitus disability. Int J Audiol. 2009;48(5):295-9. Exclude: Only determined various effects. [pmid: 19842804].
Hesser H, Pereswetoff-Morath CE, Andersson G. Consequences of controlling background sounds: The effect of experiential avoidance on tinnitus interference. Rehabil Psychol. 2009;54(4):381-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19929119].
Hesser H, Westin V, Hayes SC, et al. Clients’ in-session acceptance and cognitive defusion behaviors in acceptance-based treatment of tinnitus distress. Behav Res Ther. 2009;47(6):523-8. Exclude: Non-randomized head-to-head. [pmid: 19268281].
Hester TO, Theilman G, Green W, et al. Cyclandelate in the management of tinnitus: A randomized, placebo-controlled study. Otolaryngol Head Neck Surg. 1998;118(3:Pt 1):t-32. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9527112].
Hicks GW. Intratympanic and round-window drug therapy: Effect on cochlear tinnitus. Int Tinnitus J. 1998;4(2):144-7. Exclude: Tinnitus is somatic. [pmid: 10753404].
Higgins KM, Chen JM, Nedzelski JM, et al. A matched-pair comparison of two cochlear implant systems. J Otolaryngol. 2002;31(2):97-105. Exclude: Non-randomized head-to-head. [pmid: 12019751].
Hikita-Watanabe N, Kitahara T, Horii A, et al. Tinnitus as a prognostic factor of sudden deafness. Acta Otolaryngol. 2010;130(1):79-83. Exclude: Only determined various effects. [pmid: 19437168].
Hiller W, Goebel G. Assessing audiological, pathophysiological, and psychological variables in chronic tinnitus: A study of reliability and search for prognostic factors. Int J Behav Med. 1999;6(4):312-30. Exclude: Non-randomized head-to-head. [pmid: 16250673].
Hiller W, Goebel G. Rapid assessment of tinnitus-related psychological distress using the Mini-TQ. Int J Audiol. 2004;43(10):600-4. Exclude: Non-randomized head-to-head. [pmid: 15724525].
Hiller W, Goebel G. When tinnitus loudness and annoyance are discrepant: Audiological characteristics and psychological profile. Audiol Neuro Otol. 2007;12(6):391-400. Exclude: Only determined various effects. [pmid: 17664870].
Hinchcliffe R, Chambers C. Loudness of tinnitus: An approach to measurement. Adv Otorhinolaryngol. 1983;29:163-73. Exclude: Non-randomized head-to-head. [pmid: 6837369].
Hochberg I, Waltzman S. Comparison of pulsed and continuous tone thresholds in patients with tinnitus. Audiology. 1972;11(5):337-42. Exclude: Only determined various effects. [pmid: 4671203].
Holdefer L, Oliveira CA, Venosa AR. Group therapy for patients with tinnitus at the University of Brasilia Medical School. Revista Brasileira de Otorrinolaringologia. 2010;76(1):102-6. Exclude: Non-randomized head-to-head. [pmid: 20339697].
Holgers KM, Axelsson A, Pringle I. Ginkgo biloba extract for the treatment of tinnitus. Audiology. 1994;33(2):85-92. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8179518].
Holgers KM, Erlandsson SI, Barrenas ML. Predictive factors for the severity of tinnitus. Audiology. 2000;39(5):284-91. Exclude: Only determined various effects. [pmid: 11093613].
Holgers KM, Hakansson BE. Sound stimulation via bone conduction for tinnitus relief: A pilot study. Int J Audiol. 2002;41(5):293-300. Exclude: Case study or series. [pmid: 12166689].
Holgers KM, Zoger S, Svedlund K. Predictive factors for development of severe tinnitus suffering-further characterisation. Int J Audiol. 2005;44(10):584-92. Exclude: Non-randomized head-to-head. [pmid: 16315449].
Holm AF, Staal MJ, Mooij JJ, et al. Neurostimulation as a new treatment for severe tinnitus: A pilot study. Otol Neurotol. 428;26(3):425-8. Exclude: Case study or series. [pmid: 15891644].
Holmes S, Padgham ND. The incidence, management and consequence of tinnitus in older adults. Rev Clin Gerontol. 2008;18(4):269-85. Exclude: Not a primary study.
House JW, Miller L, House PR. Severe tinnitus: Treatment with biofeedback training (results in 41 cases). Transactions. 1977;84(4 Pt 1):697-703. Exclude: Case study or series. [pmid: 898522].
House JW. Management of the tinnitus patient. Ann Otol Rhinol Laryngol. 1981;90(6:Pt 1):597-601. Exclude: Not a primary study. [pmid: 7316384].
House JW. Therapies for tinnitus. Am J Otol. 1989;10(3):163-5. Exclude: Not a primary study. [pmid: 2665506].
House JW. Tinnitus: Evaluation and treatment. Am J Otol. 1984;5(6):472-5. Exclude: Not a primary study. [pmid: 6334995].
House JW. Treatment of severe tinnitus with biofeedback training. Laryngoscope. 1978;88(3):406-12. Exclude: Case study or series. [pmid: 628294].
House PR, House JW. The tinnitus patient: Personality and biofeedback treatment. Semin Hear. 1987;8(1):15-9. Exclude: Not a primary study.
Hu J. Acupuncture treatment of tinnitus. J Tradit Chin Med. 2004;24(3):238-40. Exclude: Case study or series. [pmid: 15510810].
Hulshof JH, Vermeij P. The effect of intra-venous lidocaine and several different doses oral tocainide HCl on tinnitus. A dose-finding study. Acta Otolaryngol. 1984;98(3–4):231-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6437131].
Hulshof JH, Vermeij P. The effect of nicotinamide on tinnitus: A double-blind controlled study. Clin Otolaryngol Allied Sci. 1987;12(3):211-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2955964].
Hulshof JH, Vermeij P. The value of carbamazepine in the treatment of tinnitus. ORL. 1985;47(5):262-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3900856].
Hulshof JH, Vermeij P. The value of flunarizine in the treatment of tinnitus. ORL. 1986;48(1):33-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3513083].
Hulshof JH, Vermeij P. The value of tocainide in the treatment of tinnitus. A double-blind controlled study. Arch Oto-Rhino-Laryngol. 1985;241(3):279-83. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3161487].
Hulshof JH, Vermey P. Section 2: Medical treatment. The effect of several doses of oral tocainide HCl on tinnitus: A dose-finding study. J Laryngol Otol. 1983;97(Suppl 9):257-8. Exclude: Not a primary study.
Hulshof JH. The loudness of tinnitus. Acta Otolaryngol. 1986;102(1–2):40-3. Exclude: Non-randomized head-to-head. [pmid: 3739691].
Hurtuk A, Dome C, Holloman CH, et al. Melatonin: Can it stop the ringing?. Ann Otol Rhinol Laryngol. 2011;120(7):433-40. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21859051].
Hutter HP, Moshammer H, Wallner P, et al. Tinnitus and mobile phone use. Occup Environ Med. 2010;67(12):804-8. Exclude: Only about prevalence. [pmid: 20573849].
Imipramine and tinnitus. J Clin Psychiatry. 1987;48(12):496-7. Exclude: Not a primary study. [pmid: 3693337].
Ince LP, Greene RY, Alba A, et al. A matching-to-sample feedback technique for training self-control of tinnitus. Health Psychol. 1987;6(2):173-82. Exclude: Case study or series. [pmid: 3830120].
Israel JM, Connelly JS, McTigue ST, et al. Lidocaine in the treatment of tinnitus aurium. A double-blind study. Arch Otolaryngol. 1982;108(8):471-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7049137].
Ito J, Sakakihara J. Suppression of tinnitus by cochlear implantation. Am J Otolaryngol. 1994;15(2):145-8. Exclude: Case study or series. [pmid: 8179106].
Ito J, Sakakihara J. Tinnitus suppression by electrical stimulation of the cochlear wall and by cochlear implantation. Laryngoscope. 1994;104(6:Pt 1):752-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8196452].
Ito J. Tinnitus suppression in cochlear implant patients. Otolaryngol Head Neck Surg. 1997;117(6):701-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9419102].
Ito M, Soma K, Ando R. Association between tinnitus retraining therapy and a tinnitus control instrument. Auris Nasus Larynx. 2009;36(5):536-40. Exclude: Non-randomized head-to-head. [pmid: 19269119].
Jackson A, MacPherson H, Hahn S. Acupuncture for tinnitus: A series of six n = 1 controlled trials. Complement Ther Med. 2006;14(1):39-46. Exclude: Case study or series. [pmid: 16473752].
Jackson P. A comparison of the effects of eighth nerve section with lidocaine on tinnitus. J Laryngol Otol. 1985;99(7):663-6. Exclude: Case study or series. [pmid: 4020258].
Jacobson GP, McCaslin DL. Clinical forum. A search for evidence of a direct relationship between tinnitus and suicide. J Am Acad Audiol. 2001;12(10):493-6. Exclude: Not a primary study. [pmid: 11791935].
Jakes S, Stephens SD. Multivariate analyses of tinnitus complaint and change in tinnitus complaint: A masker study. Br J Audiol. 1987;21(4):259-72. Exclude: Tinnitus is somatic. [pmid: 3690065].
Jakes SC, Hallam RS, Rachman S, et al. The effects of reassurance, relaxation training and distraction on chronic tinnitus sufferers. Behav Res Ther. 1986;24(5):497-507. Exclude: Case study or series. [pmid: 3530238].
Jalali MM, Kousha A, Naghavi SE, et al. The effects of alprazolam on tinnitus: A cross-over randomized clinical trial. Med Sci Monitor. 2009;15(11):I55-I60 P. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19865063].
Jang DW, Johnson E, Chandrasekhar SS. NeuromonicsTM Tinnitus Treatment: Preliminary experience in a private practice setting. Laryngoscope. 2010;120(Suppl 4):S208. Exclude: Not a primary study. [pmid: 21225806].
Jastreboff PJ, Gray WC, Gold SL. Neurophysiological approach to tinnitus patients. Am J Otol. 1996;17(2):236-40. Exclude: Not a primary study. [pmid: 8723954].
Jastreboff PJ. Tinnitus retraining therapy. Br J Audiol. 1999;33(1):68-70. Exclude: Not a primary study. [pmid: 10219725].
Javaheri S, Cohen V, Libman I, et al. Life-threatening tinnitus. Lancet. 2000;356(9226):308. Exclude: Case study or series. [pmid: 11071187].
Jayarajan V, Coles R. Treatment of tinnitus with frusemide. J Audiol Med. 1993;2(2):114-9. Exclude: Case study or series.
Jerger J. Does tinnitus actually affect quality of life?. J Am Acad Audiol. 2007;18(3):196. Exclude: Not a primary study. [pmid: 17479612].
Jerger J. Sound-based relief. J Am Acad Audiol. 2004;15(8):540. Exclude: Not a primary study. [pmid: 15553653].
Joachim S, Kronau S, Moshovel N. Test-dependent osteopathic treatment of patients suffering from craniomandibular disorders (CMD) and tinnitus. A pre-post pilot trial. Osteopathische Medizin. 2009;10(1):34. Exclude: Not a primary study.
Job A, Raynal M, Kossowski M. Susceptibility to tinnitus revealed at 2 kHz range by bilateral lower DPOAEs in normal hearing subjects with noise exposure. Audiol Neuro Otol. 2007;12(3):137-44. Exclude: Non-randomized head-to-head. [pmid: 17259699].
Johnson RM, Goodwin P. The use of audiometric tests in the management of the tinnitus patient. J Laryngol Otol Suppl. 1981;(4):48-51. Exclude: Not a primary study. [pmid: 6946170].
Jozefowicz-Korczynska M, Ciechomska EA, Pajor AM. Electronystagmography outcome and neuropsychological findings in tinnitus patients. Int Tinnitus J. 2005;11(1):54-7. Exclude: Only determined various effects. [pmid: 16419691].
Jung S, Wermker K, Poetschik H, et al. The impact of hyperbaric oxygen therapy on serological values of vascular endothelial growth factor (VEGF) and basic fibroblast growth factor (bFGF). Head Face Med. 2010;6:29. Exclude: Non-randomized head-to-head. [pmid: 21176170].
Kaada B, Hognestad S, Havstad J. Transcutaneous nerve stimulation (TNS) in tinnitus. Scand Audiol. 1989;18(4):211-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2609098].
Kaasinen S, Pyykko I, Ishizaki H, et al. Effect of intratympanically administered gentamicin on hearing and tinnitus in Meniere’s disease. Acta Otolaryngol Suppl. 1995;520:184-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8749114].
Kalcioglu MT, Bayindir T, Erdem T, et al. Objective evaluation of the effects of intravenous lidocaine on tinnitus. Hear Res. 2005;199(1–2):81-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15574302].
Kaldo V, Richards J, Andersson G. Tinnitus Stages of Change Questionnaire: Psychometric development and validation. Psychol Health Med. 2006;11(4):483-97. Exclude: Non-randomized head-to-head. [pmid: 17129924].
Kaldo-Sandstrom V, Larsen HC, Andersson G. Internet-based cognitive-behavioral self-help treatment of tinnitus: Clinical effectiveness and predictors of outcome. Am J Audiol. 2004;13(2):185-92. Exclude: Non-randomized head-to-head. [pmid: 15903144].
Kallio H, Niskanen ML, Havia M, et al. I.V. ropivacaine compared with lidocaine for the treatment of tinnitus. Br J Anaesth. 2008;101(2):261-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18522937].
Kapkin O, Satar B, Yetiser S. Transcutaneous electrical stimulation of subjective tinnitus. A placebo-controlled, randomized and comparative analysis. ORL. 2008;70(3):156-61. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18401195].
Kasemsuwan L, Jariengprasert C, Chaturapatranont S. Transtympanic gentamicin treatment in Meniere’s disease: A preliminary report. J Med Assoc Thai. 2006;89(7):979-85. Exclude: Case study or series. [pmid: 16881430].
Katon W, Sullivan M, Russo J, et al. Depressive symptoms and measures of disability: A prospective study. J Affect Disord. 1993;27(4):245-54. Exclude: Non-randomized head-to-head. [pmid: 8509525].
Kaufman AI, Gibson SA, Van de Water SM, et al. The effect of endolymphatic system surgery on tinnitus in Meniere’s disease and hydrops. J Laryngol Otol. 1983;97(Suppl 9):299-310. Exclude: Case study or series. [pmid: 6842060].
Kay NJ. Oral chemotherapy in tinnitus. Br J Audiol. 1981;15(2):123-4. Exclude: Case study or series. [pmid: 7225648].
Kearney BG, Wilson PH, Haralambous G. Stress appraisal and personality characteristics of headache patients: Comparisons with tinnitus and normal control groups. Behav Change. 1987;4(2):25-31. Exclude: Only determined various effects.
Kemp S, George RN. Masking of tinnitus induced by sound. J Speech Hear Res. 1992;35(5):1169-79. Exclude: Non-randomized head-to-head. [pmid: 1447927].
Khan M, Gross J, Haupt H, et al. A pilot clinical trial of the effects of coenzyme Q10 on chronic tinnitus aurium. Otolaryngol Head Neck Surg. 2007;136(1):72-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17210337].
Khedr EM, Abo-Elfetoh N, Rothwell JC, et al. Contralateral versus ipsilateral rTMS of temporoparietal cortex for the treatment of chronic unilateral tinnitus: Comparative study. Eur J Neurol. 2010;17(7):976-83. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20236173].
Khedr EM, Rothwell JC, El-Atar A. One-year follow up of patients with chronic tinnitus treated with left temporoparietal rTMS. Eur J Neurol. 2009;16(3):404-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19175380].
Kilpatrick JK, Sismanis A, Spencer RF, et al. Low-dose oral methotrexate management of patients with bilateral Meniere’s disease. Ear Nose Throat J. 2000;79(2):82-3. 86. 8. 91. 2. Exclude: Case study or series. [pmid: 10697931].
Kim DK, Park SN, Park KH, et al. Clinical characteristics and audiological significance of spontaneous otoacoustic emissions in tinnitus patients with normal hearing. J Laryngol Otol. 2011;125(3):246-50. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21054911].
Kim NK, Lee DH, Lee JH, et al. Bojungikgitang and banhabaekchulchonmatang in adult patients with tinnitus, a randomized, double-blind, three-arm, placebo-controlled trial--study protocol. Trials. 2010;11:34. Exclude: Not a primary study. [pmid: 20346181].
Kirsch CA, Blanchard EB, Parnes SM. A multiple-baseline evaluation of the treatment of subjective tinnitus with relaxation training and biofeedback. Biofeedback Self Regul. 1987;12(4):295-312. Exclude: Case study or series. [pmid: 3331298].
Kirsch CA, Blanchard EB, Parnes SM. Psychological characteristics of individuals high and low in their ability to cope with tinnitus. Psychosom Med. 1989;51(2):209-17. Exclude: Only determined various effects. [pmid: 2710911].
Kleinjung T, Eichhammer P, Landgrebe M, et al. Combined temporal and prefrontal transcranial magnetic stimulation for tinnitus treatment: A pilot study. Otolaryngol Head Neck Surg. 2008;138(4):497-501. Exclude: Non-randomized head-to-head. [pmid: 18359361].
Kleinjung T, Eichhammer P, Langguth B, et al. Long-term effects of repetitive transcranial magnetic stimulation (rTMS) in patients with chronic tinnitus. Otolaryngol Head Neck Surg. 2005;132(4):566-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15806046].
Kleinjung T, Steffens T, Landgrebe M, et al. Levodopa does not enhance the effect of low-frequency repetitive transcranial magnetic stimulation in tinnitus treatment. Otolaryngol Head Neck Surg. 2009;140(1):92-5. Exclude: Non-randomized head-to-head. [pmid: 19130969].
Kleinjung T, Steffens T, Landgrebe M, et al. Repetitive transcranial magnetic stimulation for tinnitus treatment: No enhancement by the dopamine and noradrenaline reuptake inhibitor bupropion. Brain Stimulation. 2011;4(2):65-70. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21511205].
Kleinjung T, Steffens T, Sand P, et al. Which tinnitus patients benefit from transcranial magnetic stimulation?. Otolaryngol Head Neck Surg. 2007;137(4):589-95. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17903575].
Ko Y, Park CW. Microvascular decompression for tinnitus. Stereotact Funct Neurosurg. 1997;68(1–4:Pt 1):266-9. Exclude: Non-randomized head-to-head. [pmid: 9711727].
Koefoed-Nielsen B, Tos M. Posttraumatic sensorineural hearing loss. A prospective long-term study. ORL. 1982;44(4):206-15. Exclude: Only about prevalence. [pmid: 7110669].
Koh TC, Fung KT. Acupuncture therapy for tinnitus. Am J Acupuncture. 1983;11(1):59-61. Exclude: Case study or series.
Koizumi T, Nishimura T, Sakaguchi T, et al. Estimation of factors influencing the results of tinnitus retraining therapy. Acta Otolaryngol Suppl. 2009;(562):40-5. Exclude: Non-randomized head-to-head. [pmid: 19848238].
Konopka W, Zalewski P, Olszewski J, et al. Tinnitus suppression by electrical promontory stimulation (EPS) in patients with sensorineural hearing loss. Auris Nasus Larynx. 2001;28(1):35-40. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 11137361].
Korres S, Mountricha A, Balatsouras D, et al. Tinnitus Retraining Therapy (TRT): Outcomes after one-year treatment. Int Tinnitus J. 2010;16(1):55-9. Exclude: Non-randomized head-to-head. [pmid: 21609915].
Krog NH, Engdahl B, Tambs K. The association between tinnitus and mental health in a general population sample: Results from the HUNT Study. J Psychosom Res. 2010;69(3):289-98. Exclude: Only determined various effects. [pmid: 20708451].
Kroner-Herwig B, Hebing G, van Rijn-Kalkmann U, et al. The management of chronic tinnitus--Comparison of a cognitive-behavioural group training with yoga. J Psychosom Res. 1995;39(2):153-65. Exclude: Non-randomized head-to-head. [pmid: 7595873].
Kroner-Herwig B, Zachriat C, Weigand D. Do patient characterisics predict outcome in the outpatient treatment of chronic tinnitus?. GMS Psycho-Social-Medicine. 2006;3:1-15. Exclude: Insufficient detail of outcome data/not extractable.
Kuk FK, Tyler RS, Rustad N, et al. Alternating current at the eardrum for tinnitus reduction. J Speech Hear Res. 1989;32(2):393-400. Exclude: Case study or series. [pmid: 2786979].
Kunkle EC. Movement-induced transient tinnitus. Ann Otol Rhinol Laryngol. 2001;110(5:Pt 1):494. Exclude: Not a primary study. [pmid: 11372937].
Kusatz M, Ostermann T, Aldridge D. Auditive stimulation therapy as an intervention in subacute and chronic tinnitus: A prospective observational study. Int Tinnitus J. 2005;11(2):163-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16639917].
Kvestad E, Czajkowski N, Engdahl B, et al. Low heritability of tinnitus: Results from the second Nord-Trondelag health study. Arch Otolaryngol Head Neck Surg. 2010;136(2):178-82. Exclude: Only about prevalence. [pmid: 20157066].
Kwee HL, Struben WH. Tinnitus and myoclonus. J Laryngol Otol. 1972;86(3):237-41. Exclude: Case study or series. [pmid: 5014915].
Labassi S, Beliaeff M. Retrospective of 1000 patients implanted with a Vibrant Soundbridge middle-ear implant. Cochlear Implants Int. 2005;6(Suppl 1):74-7. Exclude: Not a primary study. [pmid: 18792366].
Laffree JB, Vermeij P, Hulshof JH. The effect of iontophoresis of lignocaine in the treatment of tinnitus. Clin Otolaryngol Allied Sci. 1989;14(5):401-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2684451].
Lam SYR. A comparative study of acupuncture treatment in bilateral sensory deafness and tinnitus. Pac J Orient Med. 1999;(14):8-12. Exclude: Article not available.
LaMarte FP, Tyler RS. Noise-induced tinnitus. AAOHN J. 1987;35(9):403-6. Exclude: Not a primary study. [pmid: 3650081].
Lamm K. Hyperbaric oxygen therapy for the treatment of acute cochlear disorders and tinnitus. ORL. 2003;65(6):315-6. Exclude: Not a primary study. [pmid: 14981322].
Landgrebe M, Frick U, Hauser S, et al. Association of tinnitus and electromagnetic hypersensitivity: Hints for a shared pathophysiology?. PLoS ONE. 2009;4(3):e5026. Exclude: Only about prevalence. [pmid: 19325894].
Landis B, Landis E. Is biofeedback effective for chronic tinnitus? An intensive study with seven subjects. Am J Otolaryngol. 1992;13(6):349-56. Exclude: Case study or series. [pmid: 1443390].
Langenbach M, Olderog M, Michel O, et al. Psychosocial and personality predictors of tinnitus-related distress. Gen Hosp Psychiatry. 2005;27(1):73-7. Exclude: Only determined various effects. [pmid: 15694221].
Langguth B, Eichhammer P, Kreutzer A, et al. The impact of auditory cortex activity on characterizing and treating patients with chronic tinnitus--first results from a PET study. Acta Otolaryngol Suppl. 2006;(556):84-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17114149].
Langguth B, Kleinjung T, Fischer B, et al. Tinnitus severity, depression, and the big five personality traits. Progr Brain Res. 2007;166:221-5. Exclude: Only determined various effects. [pmid: 17956786].
Langguth B, Kleinjung T, Marienhagen J, et al. Transcranial magnetic stimulation for the treatment of tinnitus: Effects on cortical excitability. BMC Neurosci. 2007;8:45. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17605764].
Langguth B, Zowe M, Landgrebe M, et al. Transcranial magnetic stimulation for the treatment of tinnitus: A new coil positioning method and first results. Brain Topogr. 2006;18(4):241-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16845596].
Larsson B, Lyttkens L, Wasterstrom SA. Tocainide and tinnitus. Clinical effect and site of action. ORL. 1984;46(1):24-33. Exclude: Case study or series. [pmid: 6422376].
Lasisi AO, Abiona T, Gureje O. Tinnitus in the elderly: Profile, correlates, and impact in the Nigerian Study of Ageing. Otolaryngol Head Neck Surg. 2010;143(4):510-5. Exclude: Only about prevalence. [pmid: 20869560].
Laurikainen E, Johansson R, Akaan-Penttila E, et al. Treatment of severe tinnitus. Acta Otolaryngol Suppl. 2000;543:77-8. Exclude: Case study or series. [pmid: 10908984].
Laurikainen EA, Johansson RK, Kileny PR. Effects of intratympanically delivered lidocaine on the auditory system in humans. Ear Hear. 1996;17(1):49-54. Exclude: Case study or series. [pmid: 8741967].
Lavinsky L, Oliveira MW, Bassanesi HJ, et al. Hyperinsulinemia and tinnitus: A historical cohort. Int Tinnitus J. 2004;10(1):24-30. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15379344].
Lechtenberg R, Shulman A. Benzodiazepines in the treatment of tinnitus. J Laryngol Otol. 1983;97(Suppl 9):271-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6833853].
Lee SL, Abraham M, Cacace AT, et al. Repetitive transcranial magnetic stimulation in veterans with debilitating tinnitus: A pilot study. Otolaryngol Head Neck Surg. 2008;138(3):398-9. Exclude: Case study or series. [pmid: 18312892].
Lehner A, Schecklemann M, Landgrebe M, et al. Predictors for rTMS response in chronic tinnitus. Frontiers in Systems Neuroscience. 2012. FEBRUARY. 2012. Exclude: Non-randomized head-to-head.
Lenarz T, Gulzow J. Treatment of tinnitus with lidocaine and tocainide. Laryngol-Rhinol-Otol. 1985;64(12):49-51. Exclude: Insufficient detail of outcome data/not extractable.
Lenarz T. Treatment of tinnitus with lidocaine and tocainide. Scand Audiol Suppl. 1987;26:49-51. Exclude: Article not available. [pmid: 3107115].
Lenhardt ML, Goldstein BA, Shulman A, et al. Use of high-frequency and muscle vibration in the treatment of tinnitus. Int Tinnitus J. 2003;9(1):32-6. Exclude: Non-randomized head-to-head. [pmid: 14763327].
Letowski TR, Thompson MV. Interrupted noise as a tinnitus masker: An annoyance study. Ear Hear. 1985;6(2):65-70. Exclude: Non-randomized head-to-head. [pmid: 3996786].
Levi H, Chisin R. Can tinnitus mask hearing? A comparison between subjective audiometric and objective electrophysiological thresholds in patients with tinnitus. Audiology. 1987;26(3):153-7. Exclude: Only determined various effects. [pmid: 3662938].
Lew HL, Jerger JF, Guillory SB, et al. Auditory dysfunction in traumatic brain injury. J Rehab Res Dev. 2007;44(7):921-8. Exclude: Only about prevalence. [pmid: 18075949].
Lewis JE. Tinnitus and suicide. J Am Acad Audiol. 2002;13(6):339-41. Exclude: Not a primary study. [pmid: 12141391].
Lima AS, Sanchez TG, Bonadia Moraes MF, et al. The effect of timpanoplasty on tinnitus in patients with conductive hearing loss: A six month follow-up. Revista Brasileira de Otorrinolaringologia. 2007;73(3):384-9. Exclude: Non-randomized head-to-head. [pmid: 17684660].
Lima AS, Sanchez TG, Marcondes R, et al. The effect of stapedotomy on tinnitus in patients with otospongiosis. Ear Nose Throat J. 2005;84(7):412-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16813029].
Lindberg P, Scott B, Melin L, et al. Behavioural therapy in the clinical management of tinnitus. Br J Audiol. 1988;22(4):265-72. Exclude: Non-randomized head-to-head. [pmid: 3242716].
Lindberg P, Scott B, Melin L, et al. Long-term effects of psychological treatment of tinnitus. Scand Audiol. 1987;16(3):167-72. Exclude: Non-randomized head-to-head. [pmid: 3432995].
Lindberg P, Scott B, Melin L, et al. Matching tinnitus in natural environments with portable equipment. A new methodological approach. J Audiol Med. 1995;4(3):143-59. Exclude: Case study or series.
Lindsay M. The roaring deafness. Nurs Times. 1983;79(5):61-3. Exclude: Not a primary study. [pmid: 6550312].
Lipman RI, Lipman SP. Phase-shift treatment for predominant tone tinnitus. Otolaryngol Head Neck Surg. 2007;136(5):763-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17478212].
Loavenbruck A. Tinnitus masking devices: Safe and effective?. ASHA. 1980;22(10):857-61. Exclude: Not a primary study. [pmid: 7437091].
Long-standing adverse reactions. Med J Aust. 1993;159(9):621. Exclude: Not a primary study. [pmid: 7901742].
Lopez Gonzalez MA, Lopez FR. Sequential sound therapy in tinnitus. Acta Otorrinolaringol Espanola. 2004;55(1):2-8. Exclude: Case study or series.
Lopez-Gonzalez MA, Lopez-Fernandez R. Sequential sound therapy in tinnitus. Int Tinnitus J. 2004;10(2):150-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15732513].
Lopez-Gonzalez MA, Moliner-Peiro F, Alfaro-Garcia J, et al. Sulpiride plus hydroxyzine decrease tinnitus perception. Auris Nasus Larynx. 2007;34(1):23-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17118597].
Lopez-Gonzalez MA, Santiago AM, Esteban-Ortega F. Sulpiride and melatonin decrease tinnitus perception modulating the auditolimbic dopaminergic pathway. J Otolaryngol. 2007;36(4):213-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17942035].
Lorenz I, Muller N, Schlee W, et al. Short-term effects of single repetitive TMS sessions on auditory evoked activity in patients with chronic tinnitus. J Neurophysiol. 2010;104(3):1497-505. Exclude: Non-randomized head-to-head. [pmid: 20592125].
Loumidis KS, Hallam RS, Cadge B. The effect of written reassuring information on out-patients complaining of tinnitus. Br J Audiol. 1991;25(2):105-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2054540].
Lugli M, Romani R, Ponzi S, et al. The windowed sound therapy: A new empirical approach for an effectiv personalized treatment of tinnitus. Int Tinnitus J. 2009;15(1):51-61. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19842347].
Luxon LM. Tinnitus: Its causes, diagnosis, and treatment. BMJ. 1993;306(6891):1490-1. Exclude: Not a primary study. [pmid: 8518671].
Lyttkens L, Larsson B, Wasterstrom SA. Local anaesthetics and tinnitus. Proposed peripheral mechanism of action of lidocaine. ORL. 1984;46(1):17-23. Exclude: Case study or series. [pmid: 6700953].
Lyttkens L, Lindberg P, Scott B, et al. Treatment of tinnitus by external electrical stimulation. Scand Audiol. 1986;15(3):157-64. Exclude: Case study or series. [pmid: 3492030].
Mackenzie I, Young C, Fraser WD. Tinnitus and Paget’s disease of bone. J Laryngol Otol. 2006;120(11):899-902. Exclude: Only about prevalence. [pmid: 17040597].
Macrae J. Tinnitus and workers compensation. Aust J Audiol. 1988;10(1):17-20. Exclude: Not a primary study.
Macrae JH. Tinnitus and percentage loss of hearing. Aust J Audiol. 1992;14(1):19-23. Exclude: Not a primary study.
Maddox HE III, Porter TH. Evaluation of the tinnitus masker. Am J Otol. 1981;2(3):199-203. Exclude: Case study or series. [pmid: 7282889].
Maes IH, Joore MA, Cima RF, et al. Assessment of health state in patients with Tinnitus: A comparison of the EQ-5D and HUI Mark III. Ear Hear. 2011;32(4):428-35. Exclude: Non-randomized head-to-head. [pmid: 21221004].
Majumdar B, Mason SM, Gibbin KP. An electrocochleographic study of the effects of lignocaine on patients with tinnitus. Clin Otolaryngol Allied Sci. 1983;8(3):175-80. Exclude: Tinnitus is somatic. [pmid: 6883780].
Makishima K, Yasuda K, Myahara T, et al. Treatment of sensory-neural deafness and tinnitus with a nucleic acid derivative. Arzneimittel-Forschung. 1971;21(9):1343-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 4944968].
Man A, Naggan L. Characteristics of tinnitus in acoustic trauma. Audiology. 1981;20(1):72-8. Exclude: Non-randomized head-to-head. [pmid: 7213203].
Manage tinnitus with techniques used to treat chronic pain. Geriatrics. 2000;55(12):16. Exclude: Not a primary study. [pmid: 11131847].
Marc I. Integrative approach for tinnitus: Potential for qigong. Focus Alt Complement Ther. 2011;16(1):58. Exclude: Not a primary study.
Mardini MK. Ear-clicking “tinnitus” responding to carbamazepine. N Engl J Med. 1987;317(24):1542. Exclude: Not a primary study. [pmid: 3683492].
Markou K, Lalaki P, Barbetakis N, et al. The efficacy of medication on tinnitus due to acute acoustic trauma. Scand Audiol Suppl. 2001;52:180-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 11318462].
Markou K, Nikolaou A, Petridis DG, et al. Evaluation of various therapeutic schemes in the treatment of tinnitus due to acute acoustic trauma. J Ear Nose Throat Kbb. 2004;12(5–6):107-14. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16020985].
Marks NJ, Emery P, Onisiphorou C. A controlled trial of acupuncture in tinnitus. J Laryngol Otol. 1984;98(11):1103-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6387018].
Marks NJ, Karl H, Onisiphorou C. A controlled trial of hypnotherapy in tinnitus. Clin Otolaryngol Allied Sci. 1985;10(1):43-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3891159].
Marks NJ, Onisiphorou C, Trounce JR. The effect of single doses of amylobarbitone sodium and carbamazepine in tinnitus. J Laryngol Otol. 1981;95(9):941-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7026706].
Marlowe FI. Effective treatment of tinnitus through hypnotherapy. Am J Clin Hypnos. 1973;15(3):162-5. Exclude: Case study or series. [pmid: 4780115].
Martin FW, Colman BH. Tinnitus: A double-blind crossover controlled trial to evaluate the use of lignocaine. Clin Otolaryngol Allied Sci. 1980;5(1):3-11. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6988115].
Martines F, Bentivegna D, Martines E, et al. Assessing audiological, pathophysiological and psychological variables in tinnitus patients with or without hearing loss. Eur Arch Otorhinolaryngol. 2010;267(11):1685-93. Exclude: Only determined various effects. [pmid: 20577754].
Mason J, Rogerson D. Client-centered hypnotherapy for tinnitus: Who is likely to benefit?. Am J Clin Hypnos. 1995;37(4):294-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7741085].
Matsushima J, Kumagai M, Kamada T, et al. Preliminary study of improved perception of words with the same sound but different intonation in tinnitus patients following electrical stimulation of the ear. Acta Otolaryngol Suppl. 1997;532:112-4. Exclude: Only determined various effects. [pmid: 9442856].
Matsushima J, Kumagai M, Takeichi N, et al. Improved word perception in tinnitus patients following electrical stimulation of the ear: A preliminary report. Acta Otolaryngol Suppl. 1997;532:115-8. Exclude: Non-randomized head-to-head. [pmid: 9442857].
Matsushima J, Sakai N, Sakajiri M, et al. An experience of the usage of electrical tinnitus suppressor. Artif Organs. 1996;20(8):955-8. Exclude: Case study or series. [pmid: 8853814].
Matsushima JI, Fujimura H, Sakai N, et al. A study of electrical promontory stimulation in tinnitus patients. Auris Nasus Larynx. 1994;21(1):17-24. Exclude: Non-randomized head-to-head. [pmid: 7980190].
Maudoux A, Bonnet S, Lhonneux-Ledoux F, et al. Ericksonian hypnosis in tinnitus therapy. B-ENT. 2007;3:75-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18225612].
Mazurek B, Fischer F, Haupt H, et al. A modified version of tinnitus retraining therapy: Observing long-term outcome and predictors. Audiol Neuro Otol. 2006;11(5):276-86. Exclude: Non-randomized head-to-head. [pmid: 16717441].
McCormick MS, Thomas JN. Mexiletine in the relief of tinnitus: A report on a sequential double-blind crossover trial. Clin Otolaryngol Allied Sci. 1981;6(4):255-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7026090].
McIlwain JC. Glutamic acid in the treatment of tinnitus. J Laryngol Otol. 1987;101(6):552-4. Exclude: Tinnitus is somatic. [pmid: 2885386].
McKerrow WS, Schreiner CE, Snyder RL, et al. Tinnitus suppression by cochlear implants. Ann Otol Rhinol Laryngol. 1991;100(7):552-8. Exclude: Case study or series. [pmid: 2064266].
McShane DP, Hyde ML, Alberti PW. Tinnitus prevalence in industrial hearing loss compensation claimants. Clin Otolaryngol Allied Sci. 1988;13(5):323-30. Exclude: Only about prevalence. [pmid: 2977306].
Meehan T, Stephens D, Wilson C, et al. Aromatherapy in tinnitus: A pilot study. Audiol Med. 2003;1(2):144-7. Exclude: Case study or series.
Meeus O, Blaivie C, Ost J, et al. Influence of tonic and burst transcranial magnetic stimulation characteristics on acute inhibition of subjective tinnitus. Otol Neurotol. 2009;30(6):697-703. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19623097].
Meeus O, Heyndrickx K, Lambrechts P, et al. Phase-shift treatment for tinnitus of cochlear origin. Eur Arch Otorhinolaryngol. 2010;267(6):881-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19937045].
Megwalu UC, Finnell JE, Piccirillo JF. The effects of melatonin on tinnitus and sleep. Otolaryngol Head Neck Surg. 2006;134(2):210-3. Exclude: Non-randomized head-to-head. [pmid: 16455366].
Mehlum D, Grasel G, Fankhauser C. Prospective crossover evaluation of four methods of clinical management of tinnitus. Otolaryngol Head Neck Surg. 1984;92(4):448-53. Exclude: Case study or series. [pmid: 6435067].
Melding PS, Goodey RJ, Thorne PR. The use of intravenous lignocaine in the diagnosis and treatment of tinnitus. J Laryngol Otol. 1978;92(2):115-21. Exclude: Non-randomized head-to-head. [pmid: 627764].
Melding PS, Goodey RJ. The treatment of tinnitus with oral anticonvulsants. J Laryngol Otol. 1979;93(2):111-22. Exclude: Non-randomized head-to-head. [pmid: 429894].
Melin L, Scott B, Lindberg P, et al. Hearing aids and tinnitus--An experimental group study. Br J Audiol. 1987;21(2):91-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3594019].
Memin Y. Perceived efficacy of cyclandelate in the treatment of cochleovestibular and retinal disturbances related to cerebrovascular insufficiency. A study in general practice comprising 2772 patients. Drugs. 1987;33(Suppl 2):120-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3497796].
Menkes DB, Larson PM. Sodium valproate for tinnitus. J Neurol Neurosurg Psychiatry. 1998;65(5):803. Exclude: Not a primary study. [pmid: 9810969].
Mennemeier M, Chelette KC, Allen S, et al. Variable changes in PET activity before and after rTMS treatment for tinnitus. Laryngoscope. 2011;121(4):815-22. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21287564].
Merchant SN, Merchant N. Intravenous lignocaine in tinnitus. J Postgrad Med. 1985;31(2):80-2. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 4057118].
Mielczarek M, Konopka W, OJ. Tinnitus treatment by using electrical stimulation. Otolaryngol Pol. 2007;61(5):902-4. Exclude: Article not available. [pmid: 18552045].
Miguel Ramirez AL, Pablo Sandoval OG, Ernesto BL, et al. Treatment and follow-up of referred otic symptomatology in 23 patients with diagnosed temporomandibular disorders. Audiol Med. 2006;4(2):73-81. Exclude: Case study or series.
Mihail RC, Crowley JM, Walden BE, et al. The tricyclic trimipramine in the treatment of subjective tinnitus. Ann Otol Rhinol Laryngol. 1988;97(2:Pt 1):120-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3355041].
Mineau SM, Schlauch RS. Threshold measurement for patients with tinnitus: Pulsed or continuous tones. Am J Audiol. 1997;6(1):52-6. Exclude: Article not available.
Mitchell CR, Vernon JA, Creedon TA. Measuring tinnitus parameters: Loudness, pitch, and maskability. J Am Acad Audiol. 1993;4(3):139-51. Exclude: Article not available. [pmid: 8318704].
Miyano K. Tinnitus and bruxing. J Am Dent Assoc. 1038;134(8):1036. Exclude: Not a primary study. [pmid: 12956337].
Mo B, Harris S, Lindbaek M. Tinnitus in cochlear implant patients--A comparison with other hearing-impaired patients. Int J Audiol. 2002;41(8):527-34. Exclude: Only about prevalence. [pmid: 12477173].
Moffat G, Adjout K, Gallego S, et al. Effects of hearing aid fitting on the perceptual characteristics of tinnitus. Hear Res. 2009;254(1–2):82-91. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19409969].
Molini E, Faralli M, Calenti C, et al. Personal experience with tinnitus retraining therapy. Eur Arch Otorhinolaryngol. 2010;267(1):51-6. Exclude: Case study or series. [pmid: 19543742].
Moller AR. A double-blind placebo-controlled trial of baclofen in the treatment of tinnitus. Am J Otol. 1997;18(2):268-9. Exclude: Not a primary study. [pmid: 9093691].
Moller C, Odkvist LM, Thell J, et al. Vestibular and audiologic functions in gentamicin-treated Meniere’s disease. Am J Otol. 1988;9(5):383-91. Exclude: Case study or series. [pmid: 3202127].
Moller MB, Moller AR, Jannetta PJ, et al. Vascular decompression surgery for severe tinnitus: Selection criteria and results. Laryngoscope. 1993;103(4:Pt 1):421-7. Exclude: Case study or series. [pmid: 8459751].
Moody-Antonio S, House JW. Hearing outcome after concurrent endolymphatic shunt and vestibular nerve section. Otol Neurotol. 2003;24(3):453-9. Exclude: Non-randomized head-to-head. [pmid: 12806298].
Mora R, Salami A, Barbieri M, et al. The use of sodium enoxaparin in the treatment of tinnitus. Int Tinnitus J. 2003;9(2):109-11. Exclude: Non-randomized head-to-head. [pmid: 15106284].
Morales-Garcia C, Quiroz G, Matamala JM, et al. Neuro-otological findings in tinnitus patients with normal hearing. J Laryngol Otol. 2010;124(5):474-6. Exclude: Only determined various effects. [pmid: 20003596].
Morgan DH. Dysfunction, pain, tinnitus, vertigo corrected by mandibular joint surgery. J South Calif Dent Assoc. 1971;39(7):505-34. Exclude: Not a primary study. [pmid: 5314744].
Morgenstern C, Biermann E. The efficacy of Ginkgo special extract EGb 761 in patients with tinnitus. Int J Clin Pharmacol Ther. 2002;40(5):188-97. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 12051570].
Mrena R, Savolainen S, Kiukaanniemi H, et al. The effect of tightened hearing protection regulations on military noise-induced tinnitus. Int J Audiol. 2009;48(6):394-400. Exclude: Non-randomized head-to-head. [pmid: 19925346].
Mrena R, Ylikoski M, Makitie A, et al. Occupational noise-induced hearing loss reports and tinnitus in Finland. Acta Otolaryngol. 2007;127(7):729-35. Exclude: Only about prevalence. [pmid: 17573569].
Muhammad Gadit AA. Transcranial magnetic stimulation (TMS): Should we officially include this form of treatment?. J Pakistan Med Assoc. 2008;58(7):413-4. Exclude: Not a primary study.
Muluk NB, Oguzturk O. Occupational noise-induced tinnitus: Does it affect workers’ quality of life?. J Otolaryngol Head Neck Surg. 2008;37(1):65-71. Exclude: Only determined various effects. [pmid: 18479630].
Muluk NB, Tuna E, Arikan OK. Effects of subjective tinnitus on sleep quality and Mini Mental Status Examination scores. B-ENT. 2010;6(4):271-80. Exclude: Only determined various effects. [pmid: 21302690].
Muluk NB. The SF-36 Health Survey in tinnitus patients with a high jugular bulb. J Otolaryngol Head Neck Surg. 2009;38(2):166-71. Exclude: Only determined various effects. [pmid: 19442364].
Murata Y. Treatment of cochlear-tinnitus with dexamethasone infusion into the tympanic cavity as steroid targeting therapy. J Saitama Med Sch. 1997;24(4):201-10. Exclude: Article not available.
Muroi M, Ito F. Patients exhibiting tinnitus aurium with a history of cerebral infarction clinical characteristics and pathogenesis. Kitakanto Med J. 1998;48(1):45-8. Exclude: Tinnitus is somatic.
Murtagh J. Patient education. Tinnitus. Aust Fam Physician. 1994;23(6):1102. Exclude: Not a primary study. [pmid: 8053844].
Nageris BI, Attias J, Raveh E. Test-retest tinnitus characteristics in patients with noise-induced hearing loss. Am J Otolaryngol. 2010;31(3):181-4. Exclude: Non-randomized head-to-head. [pmid: 20015738].
Nagler S. Lemonade out of lemons--Tinnitus retraining therapy. J Med Assoc Ga. 1998;87(3):220-3. Exclude: Not a primary study. [pmid: 9747080].
Narozny W, Kuczkowski J, Mikaszewski B. Measuring severity of tinnitus with a visual analog scale. Am Fam Physician. 2005;71(5):855-6. Exclude: Not a primary study. [pmid: 15768613].
Neher A. Tinnitus. South Med J. 1989;82(12):1589. Exclude: Not a primary study. [pmid: 2595438].
Neher A. Tracking tinnitus hunches. Am Fam Physician. 1989;40(6):48. Exclude: Not a primary study. [pmid: 2589150].
Neher A. Treatment for tinnitus. J Gen Intern Med. 1990;5(1):93. Exclude: Not a primary study. [pmid: 2299434].
Newman CW, Sandridge SA, Bolek L. Development and psychometric adequacy of the screening version of the tinnitus handicap inventory. Otol Neurotol. 2008;29(3):276-81. Exclude: Non-randomized head-to-head. [pmid: 18277308].
Newman CW, Sandridge SA, Jacobson GP. Psychometric adequacy of the Tinnitus Handicap Inventory (THI) for evaluating treatment outcome. J Am Acad Audiol. 1998;9(2):153-60. Exclude: Non-randomized head-to-head. [pmid: 9564679].
Newman CW, Sandridge SA. A comparison of benefit and economic value between two sound therapy tinnitus management options. J Am Acad Audiol. 2012;23(2):126-38. Exclude: Non-randomized head-to-head. [pmid: 22353681].
Newman CW, Wharton JA, Shivapuja BG, et al. Relationships among psychoacoustic judgments, speech understanding ability and self-perceived handicap in tinnitus subjects. Audiology. 1994;33(1):47-60. Exclude: Only determined various effects. [pmid: 8129680].
Nilsson S, Axelsson A, Li DG. Acupuncture for tinnitus management. Scand Audiol. 1992;21(4):245-51. Exclude: Non-randomized head-to-head. [pmid: 1488611].
Nissen AJ. Medical and surgical management of tinnitus. Semin Hear. 1987;8(1):1-5. Exclude: Not a primary study.
Noble W. Tinnitus self-assessment scales: Domains of coverage and psychometric properties. Hear J. 2001;54(11):20-5. Exclude: Not a primary study.
Nodar RH, Lovering LJ. Subjective and objective measurement of vibratory tinnitus. Eye Ear Nose Throat Mo. 1971;50(8):302-5. Exclude: Tinnitus is somatic. [pmid: 5565014].
Nondahl DM, Cruickshanks KJ, Wiley TL, et al. Prevalence and 5-year incidence of tinnitus among older adults: The epidemiology of hearing loss study. J Am Acad Audiol. 2002;13(6):323-31. Exclude: Only about prevalence. [pmid: 12141389].
Nondahl DM, Klein BE, Klein R, et al. Factors predicting severity of tinnitus: A population-based assessment. J Am Acad Audiol. 2005;16(3):196. Exclude: Not a primary study. [pmid: 15844744].
Nottet JB, Moulin A, Brossard N, et al. Otoacoustic emissions and persistent tinnitus after acute acoustic trauma. Laryngoscope. 2006;116(6):970-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16735910].
Novotny M, Kostrica R, Cirek Z. The efficacy of Arlevert therapy for vertigo and tinnitus. Int Tinnitus J. 1999;5(1):60-2. Exclude: Non-randomized head-to-head. [pmid: 10753423].
Nozawa I, Nakayama H, Hashimoto K, et al. Efficacy of long-term administration of isosorbide for Meniere’s disease. ORL. 1995;57(3):135-40. Exclude: Case study or series. [pmid: 7603692].
Objective evaluation: Quantitative assessment and measurement of tinnitus; Clinical experience. J Laryngol Otol Suppl. 1984;9:145-92. Exclude: Article not available. [pmid: 6596357].
O’Connor S, Hawthorne M, Britten SR, et al. The management of a population of tinnitus sufferers in a specialized clinic: Part II. Identification of psychiatric morbidity in a population of tinnitus sufferers. J Laryngol Otol. 1987;101(8):791-4. Exclude: Non-randomized head-to-head. [pmid: 3655531].
Odkvist LM. Middle ear ototoxic treatment for inner ear disease. Acta Otolaryngol Suppl. 1989;107(457):83-6. Exclude: Tinnitus is somatic. [pmid: 2929339].
Ogata Y, Sekitani T, Moriya K, et al. Biofeedback therapy in the treatment of tinnitus. Auris Nasus Larynx. 1993;20(2):95-101. Exclude: Case study or series. [pmid: 8216052].
Ogawa K, Takei S, Inoue Y, et al. Effect of prostaglandin E1 on idiopathic sudden sensorineural hearing loss: A double-blinded clinical study. Otol Neurotol. 2002;23(5):665-8. Exclude: Non-randomized head-to-head. [pmid: 12218617].
Ohsaki K, Ueno M, Zheng HX, et al. Evaluation of tinnitus patients by peroral multi-drug treatment. Auris Nasus Larynx. 1998;25(2):149-54. Exclude: Case study or series. [pmid: 9673727].
Oishi N, Kanzaki S, Shinden S, et al. Effects of selective serotonin reuptake inhibitor on treating tinnitus in patients stratified for presence of depression or anxiety. Audiol Neuro Otol. 2010;15(3):187-93. Exclude: Non-randomized head-to-head. [pmid: 19851065].
Okada DM, Onishi ET, Chami FI, et al. Acupuncture for tinnitus immediate relief. Revista Brasileira de Otorrinolaringologia. 2006;72(2):182-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16951850].
Okamoto H, Stracke H, Stoll W, et al. Listening to tailor-made notched music reduces tinnitus loudness and tinnitus-related auditory cortex activity. Proceedings of the National Academy of Sciences of the United States of America. 2010;107(3):1207-10. Excluded at Title & Abstract, reconsidered at request of Peer Reviewer, not eligible for this report. [pmid: 20080545].
Okhovat A, Berjis N, Okhovat H, et al. Low-level laser for treatment of tinnitus: A self-controlled clinical trial. J Res Med Sci. 2011;16(1):33-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21448380].
Okusa M, Shiraishi T, Kubo T, et al. Tinnitus suppression by electrical promontory stimulation in sensorineural deaf patients. Acta Otolaryngol Suppl. 1993;501:54-8. Exclude: Case study or series. [pmid: 8447227].
Oliveira CA, Venosa A, Araujo MF. Tinnitus program at Brasilia University Medical School. Int Tinnitus J. 1999;5(2):141-3. Exclude: Only about prevalence. [pmid: 10753434].
Oliveira CA. How does stapes surgery influence severe disabling tinnitus in otosclerosis patients?. Adv Otorhinolaryngol. 2007;65:343-7. Exclude: Non-randomized head-to-head. [pmid: 17245070].
Olivier J, Plath P. Combined low power laser therapy and extracts of Ginkgo biloba in a blind trial of treatment for tinnitus. Laser Ther. 1993;5(3):137-9. Exclude: Insufficient detail of outcome data/not extractable.
Omura Y. Simple custom-made disposable surface electrode system for non-invasive “electro-acupuncture” or TNS and its clinical applications including treatment of cephalic hypertension and hypotension syndromes as well as temporo-mandibular joint problems, tinnitus, shoulder and lower back pain, etc. Acupuncture Eletctro Ther Res. 1981;6(2–3):109-34. Exclude: Not a primary study. [pmid: 6120617].
Oosterveld WJ. Flunarizine in vertigo. A double-blind placebo-controlled cross-over evaluation of a constant-dose schedule. ORL. 1982;44(2):72-80. Exclude: Tinnitus is somatic. [pmid: 7041040].
Otsuka K, Pulec JL, Suzuki M. Assessment of intravenous lidocaine for the treatment of subjective tinnitus. Ear Nose Throat J. 2003;82(10):781-4. Exclude: Case study or series. [pmid: 14606175].
Ozcankaya R, Dogru H. Depression and anxiety symptoms in tinnitus patients. Biomed Res. 2001;12(3):221-4. Exclude: Only determined various effects.
Paaske PB, Pedersen CB, Kjems G, et al. Zinc in the management of tinnitus. Placebo-controlled trial. Ann Otol Rhinol Laryngol. 1991;100(8):647-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 1872515].
Pan T, Tyler RS, Ji H, et al. Changes in the tinnitus handicap questionnaire after cochlear implantation. Am J Audiol. 2009;18(2):144-51. Exclude: Non-randomized head-to-head. [pmid: 19949236].
Pang LQ, Pang MK, Takumi MM. A new method of managing subjective tinnitus. Hawaii Med J. 1979;38(8):235-9. Exclude: Case study or series. [pmid: 511527].
Parker WS, Chole RA. Tinnitus, vertigo, and temporomandibular disorders. Am J Orthod Dentofacial Orthop. 1995;107(2):153-8. Exclude: Only about prevalence. [pmid: 7847272].
Parkin JL. Tinnitus evaluation. Am Fam Physician. 1973;8(3):151-5. Exclude: Not a primary study. [pmid: 4542333].
Paul J, Brown NM. Tinnitus and ciprofloxacin. BMJ. 1995;311(6999):232. Exclude: Case study or series. [pmid: 7627041].
Paul RG, Dennis KC. Face-to-face. What about tinnitus?. Am J Audiol. 1996;5(1):5-8. Exclude: Article not available.
Pawlak-Osinska K, Kazmierczak H, Kazmierczak W, et al. Ozone therapy and pressure-pulse therapy in Meniere’s disease. Int Tinnitus J. 2004;10(1):54-7. Exclude: Case study or series. [pmid: 15379351].
Penner MJ. Judgments and measurements of the loudness of tinnitus before and after masking. J Speech Hear Res. 1988;31(4):582-7. Exclude: Case study or series. [pmid: 3230887].
Perrin E, Degive C, Kos I, et al. Follow-up of a cohort of tinnitus patients attending a medical-psychological joint consultation. Oto-Rhino-Laryngol Nova. 2000;10(1):28-31. Exclude: Case study or series.
Perucca E, Jackson P. A controlled study of the suppression of tinnitus by lidocaine infusion: (Relationship of therapeutic effect with serum lidocaine levels). J Laryngol Otol. 1985;99(7):657-61. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 4020257].
Piccirillo JF, Garcia KS, Nicklaus J, et al. Low-frequency repetitive transcranial magnetic stimulation to the temporoparietal junction for tinnitus. Arch Otolaryngol Head Neck Surg. 2011;137(3):221-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21422304].
Pilgramm M, Schumann K. Hyperbaric oxygen therapy for acute acoustic trauma. Arch Oto-Rhino-Laryngol. 1985;241(3):247-57. Exclude: Tinnitus is somatic. [pmid: 4026691].
Pineda JA, Moore FR, Viirre E. Tinnitus treatment with customized sounds. Int Tinnitus J. 2008;14(1):17-25. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18616082].
Pinto PC, Sanchez TG, Tomita S. The impact of gender, age and hearing loss on tinnitus severity. Revista Brasileira de Otorrinolaringologia. 2010;76(1):18-24. Exclude: Only about prevalence. [pmid: 20339684].
Plath P, Olivier J. Results of combined low-power laser therapy and extracts of Ginkgo biloba in cases of sensorineural hearing loss and tinnitus. Adv Otorhinolaryngol. 1995;49:101-4. Exclude: Not a primary study. [pmid: 7653339].
Plewnia C, Bartels M, Gerloff C. Transient suppression of tinnitus by transcranial magnetic stimulation. Ann Neurol. 2003;53(2):263-6. Exclude: Non-randomized head-to-head. [pmid: 12557296].
Plewnia C, Reimold M, Najib A, et al. Dose-dependent attenuation of auditory phantom perception (tinnitus) by PET-guided repetitive transcranial magnetic stimulation. Hum Brain Mapp. 2007;28(3):238-46. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16773635].
Plewnia C, Reimold M, Najib A, et al. Moderate therapeutic efficacy of positron emission tomography-navigated repetitive transcranial magnetic stimulation for chronic tinnitus: A randomised, controlled pilot study. J Neurol Neurosurg Psychiatry. 2007;78(2):152-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16891384].
Podoshin L, Ben-David Y, Fradis M, et al. Idiopathic subjective tinnitus treated by amitriptyline hydrochloride/biofeedback. Int Tinnitus J. 1995;1(1):54-60. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10753321].
Podoshin L, Fradis M, David YB. Treatment of tinnitus by intratympanic instillation of lignocaine (lidocaine) 2 per cent through ventilation tubes. J Laryngol Otol. 1992;106(7):603-6. Exclude: Case study or series. [pmid: 1527456].
Poreisz C, Boros K, Antal A, et al. Safety aspects of transcranial direct current stimulation concerning healthy subjects and patients. Brain Res Bull. 2007;72(4–6):208-14. Exclude: Non-randomized head-to-head. [pmid: 17452283].
Poreisz C, Paulus W, Moser T, et al. Does a single session of theta-burst transcranial magnetic stimulation of inferior temporal cortex affect tinnitus perception?. BMC Neurosci. 2009;10:54. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19480651].
Portmann M, Cazals Y, Negrevergne M, et al. Temporary tinnitus suppression in man through electrical stimulation of the cochlea. Acta Otolaryngol. 1979;87(3–4):294-9. Exclude: Case study or series. [pmid: 312586].
Pothier DD, Bredenkamp CL. The placebo effect of transcutaneous electrical nerve stimulation. J Laryngol Otol. 2006;120:442-5. [pmid: 16556347]. J Laryngol Otol. 2008;122(2):217. Exclude: Not a primary study. [pmid: 18252020].
Prestes R, Daniela G. Impact of tinnitus on quality of life, loudness and pitch match, and high-frequency audiometry. Int Tinnitus J. 2009;15(2):134-8. Exclude: Only determined various effects. [pmid: 20420337].
Prinz RJ. Assessment of treatments for subjective phenomena. Semin Hear. 1987;8(1):63-9. Exclude: Not a primary study.
Protheroe D, House A. Treatments for tinnitus. BMJ. 1993;307(6902):505. Exclude: Not a primary study. [pmid: 8400956].
Pugh RS, Stephens D, Budd R. The contribution of spouse responses and marital satisfaction to the experience of chronic tinnitus. Audiol Med. 2004;2(1):60-73. Exclude: Only determined various effects.
Pulec JL. Cochlear nerve section for intractable tinnitus. Ear Nose Throat J. 1995;74(7):468-6. Exclude: Case study or series. [pmid: 7671835].
Qian X. Experience in the clinical application of zhongzhu (TE 3). J Tradit Chin Med. 2004;24(4):282-3. Exclude: Not a primary study. [pmid: 15688696].
Quaranta A, Scaringi A, Aloisi A, et al. Intratympanic therapy for Meniere’s disease: Effect of administration of low concentration of gentamicin. Acta Otolaryngol. 2001;121(3):387-92. Exclude: Tinnitus is somatic. [pmid: 11425206].
Quaranta N, Fernandez-Vega S, D’elia C, et al. The effect of unilateral multichannel cochlear implant on bilaterally perceived tinnitus. Acta Otolaryngol. 2008;128(2):159-63. Exclude: Non-randomized head-to-head. [pmid: 17851950].
Rahko T, Kotti V. Tinnitus treatment by transcutaneous nerve stimulation (TNS). Acta Otolaryngol Suppl. 1997;529:88-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9288279].
Ramkumar V, Rangasayee R. Studying tinnitus in the ICF framework. Int J Audiol. 2010;49(9):645-50. Exclude: Only determined various effects. [pmid: 20707669].
Rask-Andersen H, Friberg U, Johansson M, et al. Effects of intratympanic injection of latanoprost in Meniere’s disease: A randomized, placebo-controlled, double-blind, pilot study. Otolaryngol Head Neck Surg. 2005;133(3):441-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16143197].
Ratnayake SA, Jayarajan V, Bartlett J. Could an underlying hearing loss be a significant factor in the handicap caused by tinnitus?. Noise Health. 2009;11(44):156-60. Exclude: Non-randomized head-to-head. [pmid: 19602769].
Raza SA, Phillipps JJ. Vertigo, hearing loss, and tinnitus. Postgrad Med J. 1998;74(872):375-7. Exclude: Not a primary study. [pmid: 9799900].
Reed HT, Meltzer J, Crews P, et al. Amino-oxyacetic acid as a palliative in tinnitus. Arch Otolaryngol. 1985;111(12):803-5. Exclude: Tinnitus is somatic. [pmid: 2415097].
Reich GE, Johnson RM. Personality characteristics of tinnitus patients. J Laryngol Otol. 1983;97(Suppl 9):228-32. Exclude: Non-randomized head-to-head.
Reisser CH, Weidauer H. Ginkgo biloba extract EGb 761 or pentoxifylline for the treatment of sudden deafness: A randomized, reference-controlled, double-blind study. Acta Otolaryngol. 2001;121(5):579-84. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 11583389].
Rendell RJ, Carrick DG, Fielder CP, et al. Low-powered ultrasound in the inhibition of tinnitus. Br J Audiol. 1987;21(4):289-93. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3318977].
Riihikangas P, Anttonen H, Hassi J, et al. Hearing loss and impulse noise during military service. Scand Audiol Suppl. Suppl 12. 1980:292-7. Exclude: Only about prevalence. [pmid: 6939100].
Risey J, Briner W, Guth PS, et al. The superiority of the Goodwin procedure over the traditional procedure in measuring the loudness level of tinnitus. Ear Hear. 1989;10(5):318-22. Exclude: Non-randomized head-to-head. [pmid: 2792585].
Roberts C, Inamdar A, Koch A, et al. A randomized, controlled study comparing the effects of vestipitant or vestipitant and paroxetine combination in subjects with tinnitus. Otol Neurotol. 2011;32(5):721-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21646935].
Robinson M. Tinnitus and otosclerosis surgery. J Laryngol Otol. 1983;97(Suppl 9):294-8. Exclude: Tinnitus is somatic.
Robinson SK, McQuaid JR, Viirre ES, et al. Relationship of tinnitus questionnaires to depressive symptoms, quality of well-being, and internal focus. Int Tinnitus J. 2003;9(2):97-103. Exclude: Only determined various effects. [pmid: 15106282].
Robinson SK, Viirre ES, Bailey KA, et al. A randomized controlled trial of cognitive-behavior therapy for tinnitus. Int Tinnitus J. 2008;14(2):119-26. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19205162].
Rocha CA, Sanchez TG. Myofascial trigger points: Another way of modulating tinnitus. Progr Brain Res. 2007;166:209-14. Exclude: Not a primary study. [pmid: 17956784].
Roeser RJ, Price DR. Clinical experience with tinnitus maskers. Ear Hear. 1980;1(2):63-8. Exclude: Case study or series. [pmid: 7372018].
Rosenberg SI, Silverstein H, Rowan PT, et al. Effect of melatonin on tinnitus. Laryngoscope. 1998;108(3):305-10. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9504599].
Rosenhall U, Karlsson AK. Tinnitus in old age. Scand Audiol. 1991;20(3):165-71. Exclude: Only about prevalence. [pmid: 1842285].
Ross UH, Lange O, Unterrainer J, et al. Ericksonian hypnosis in tinnitus therapy: Effects of a 28-day inpatient multimodal treatment concept measured by Tinnitus-Questionnaire and Health Survey SF-36. Eur Arch Otorhinolaryngol. 2007;264(5):483-8. Exclude: Non-randomized head-to-head. [pmid: 17206402].
Rossi S, De CA, Ulivelli M, et al. Effects of repetitive transcranial magnetic stimulation on chronic tinnitus: A randomised, crossover, double blind, placebo controlled study. J Neurol Neurosurg Psychiatry. 2007;78(8):857-63. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17314192].
Rossiter S, Stevens C, Walker G. Tinnitus and its effect on working memory and attention. J Speech Lang Hear Res. 2006;49(1):150-60. Exclude: Only determined various effects. [pmid: 16533080].
Roydhouse N. Multiple tinnitus. NZ Med J. 1989;102(879):594. Exclude: Case study or series. [pmid: 2812600].
Rubak T, Kock S, Koefoed-Nielsen B, et al. The risk of tinnitus following occupational noise exposure in workers with hearing loss or normal hearing. Int J Audiol. 2008;47(3):109-14. Exclude: Only about prevalence. [pmid: 18307090].
Rubin W. Tinnitus evaluations: Aids to diagnosis and treatment. J Laryngol Otol. 1983;97(Suppl 9):178-80. Exclude: Not a primary study.
Rubinstein B, Carlsson GE. Effects of stomatognathic treatment on tinnitus: A retrospective study. Cranio. 1987;5(3):254-9. Exclude: Non-randomized head-to-head. [pmid: 3476212].
Ruckenstein MJ, Hedgepeth C, Rafter KO, et al. Tinnitus suppression in patients with cochlear implants. Otol Neurotol. 2001;22(2):200-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 11300269].
Sadlier M, Stephens SD, Kennedy V. Tinnitus rehabilitation: A mindfulness meditation cognitive behavioural therapy approach. J Laryngol Otol. 2008;122(1):31-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17451612].
Sadlier M, Stephens SD. An approach to the audit of tinnitus management. J Laryngol Otol. 1995;109(9):826-9. Exclude: Non-randomized head-to-head. [pmid: 7494113].
Sakai M, Sato M, Iida M, et al. The effect on tinnitus of stapes surgery for otosclerosis. Rev Laryngol Otol Rhinol. 1995;116(1):27-30. Exclude: Tinnitus is somatic. [pmid: 7644843].
Sakaki T, Morimoto T, Miyamoto S, et al. Microsurgical treatment of patients with vestibular and cochlear symptoms. Surg Neurol. 1987;27(2):141-6. Exclude: Tinnitus is somatic. [pmid: 3492773].
Sakata H, Kojima Y, Koyama S, et al. Treatment of cochlear tinnitus with transtympanic infusion of 4% lidocaine into the tympanic cavity. Int Tinnitus J. 2001;7(1):46-50. Exclude: Article not available. [pmid: 14964956].
Sala T. Transtympanic administration of aminoglycosides in patients with Meniere’s disease. Arch Oto-Rhino-Laryngol. 1988;245(5):293-6. Exclude: Non-randomized head-to-head.
Salama NY, Bhatia P, Robb PJ. Efficacy of oral oxpentifylline in the management of idiopathic tinnitus. ORL. 1989;51(5):300-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2682431].
Salembier L, De RD, Van de Heyning PH. The use of flupirtine in treatment of tinnitus. Acta Otolaryngol Suppl. 2006;(556):93-5. Exclude: Non-randomized head-to-head. [pmid: 17114151].
Salley LH Jr, Grimm M, Sismanis A, et al. Methotrexate in the management of immune mediated cochleovestibular disorders: Clinical experience with 53 patients. J Rheumatol. 2001;28(5):1037-40. Exclude: Case study or series. [pmid: 11361185].
Salonen J, Johansson R, Joukamaa M. Alexithymia, depression and tinnitus in elderly people. Gen Hosp Psychiatry. 2007;29(5):431-5. Exclude: Only about prevalence. [pmid: 17888810].
Salvi R, Sun W, Lobarinas E. Clinical and scientific aspects of tinnitus: Part II. Semin Hear. 2008;29(4):311. Exclude: Not a primary study.
Salvi R, Sun W, Lobarinas E. Clinical and scientific aspects of tinnitus. Semin Hear. 2008;29(3):229-30. Exclude: Not a primary study.
Sanches SG, Samelli AG, Nishiyama AK, et al. GIN Test (Gaps-in-Noise) in normal listeners with and without tinnitus. Profono. 2010;22(3):257-62. Exclude: Only determined various effects. [pmid: 21103715].
Sanchez L, Stephens SDG. Perceived problems of tinnitus clinic clients at long-term follow up. J Audiol Med. 2000;9(2):94-103. Exclude: Non-randomized head-to-head.
Sanchez TG, Balbani AP, Bittar RS, et al. Lidocaine test in patients with tinnitus: Rationale of accomplishment and relation to the treatment with carbamazepine. Auris Nasus Larynx. 1999;26(4):411-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10530736].
Sanchez TG, da Silva LA, Brandao AL, et al. Somatic modulation of tinnitus: Test reliability and results after repetitive muscle contraction training. Ann Otol Rhinol Laryngol. 2007;116(1):30-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17305275].
Sanchez TG, Medeiros IR, Levy CP, et al. Tinnitus in normally hearing patients: Clinical aspects and repercussions. Revista Brasileira de Otorrinolaringologia. 2005;71(4):427-31. Exclude: Only determined various effects. [pmid: 16446955].
Santoni CB, Fiorini AC. Pop-rock musicians: Assessment of their satisfaction provided by hearing protectors. Revista Brasileira de Otorrinolaringologia. 2010;76(4):454-61. Exclude: Non-randomized head-to-head. [pmid: 20835532].
Savastano M, Brescia G, Marioni G. Antioxidant therapy in idiopathic tinnitus: Preliminary outcomes. Arch Med Res. 2007;38(4):456-9. Exclude: Non-randomized head-to-head. [pmid: 17416295].
Savastano M. Lidocaine intradermal injection--a new approach in tinnitus therapy: Preliminary report. Adv Ther. 2004;21(1):13-20. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15191153].
Schaette R, Konig O, Hornig D, et al. Acoustic stimulation treatments against tinnitus could be most effective when tinnitus pitch is within the stimulated frequency range. Hear Res. 2010;269(1–2):95-101. Exclude: Non-randomized head-to-head. [pmid: 20619332].
Schleuning AJ, Johnson RM, Vernon JA. Evaluation of a tinnitus masking program: A follow-up study of 598 patients. Ear Hear. 1980;1(2):71-4. Exclude: Case study or series. [pmid: 7372020].
Schmitt C, Patak M, Kroner-Herwig B. Stress and the onset of sudden hearing loss and tinnitus. Int Tinnitus J. 2000;6(1):41-9. Exclude: Non-randomized head-to-head. [pmid: 14689617].
Schmuziger N, Patscheke J, Probst R. Hearing in nonprofessional pop/rock musicians. Ear Hear. 2006;27(4):321-30. Exclude: Only about prevalence. [pmid: 16825883].
Scholz BA, Holmes HM, Marcus DM. Use of herbal medications in elderly patients. Ann Long Term Care. 2008;16(12):24-8. Exclude: Not a primary study.
Schutte NS, Noble W, Malouff JM, et al. Evaluation of a model of distress related to tinnitus. Int J Audiol. 2009;48(7):428-32. Exclude: Case study or series. [pmid: 19925329].
Scott B, Larsen HC, Lyttkens L, et al. An experimental evaluation of the effects of transcutaneous nerve stimulation (TNS) and applied relaxation (AR) on hearing ability, tinnitus and dizziness in patients with Meniere’s disease. Br J Audiol. 1994;28(3):131-40. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7841897].
Scott B, Lindberg P, Lyttkens L, et al. Psychological treatment of tinnitus. An experimental group study. Scand Audiol. 1985;14(4):223-30. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3912955].
Searchfield GD, Jerram C, Wise K, et al. The impact of hearing loss on tinnitus severity. Aust NZ J Audiol. 2007;29(2):67-76. Exclude: Insufficient detail of outcome data/not extractable.
Searchfield GD, Morrison-Low J, Wise K. Object identification and attention training for treating tinnitus. Progr Brain Res. 2007;166:441-60. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17956809].
Segal NT, Puterman M, Shkolnik M, et al. The role of tinnitus evaluation tests in differentiating functional versus organic tinnitus. Otolaryngol Head Neck Surg. 2007;137(5):772-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17967644].
Seidman MD, Ridder DD, Elisevich K, et al. Direct electrical stimulation of Heschl’s gyrus for tinnitus treatment. Laryngoscope. 2008;118(3):491-500. Exclude: Case study or series. [pmid: 18094653].
Seydel C, Haupt H, Szczepek AJ, et al. Long-term improvement in tinnitus after modified tinnitus retraining therapy enhanced by a variety of psychological approaches. Audiol Neuro Otol. 2010;15(2):69-80. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19657182].
Shaladi AM, Crestani F, Saltari R. Auricular acupuncture plus antioxidants in the treatment of subjective tinnitus: A case series. Med Acupuncture. 2009;21(2):131-4. Exclude: Case study or series.
Shambaugh GE Jr. Zinc for tinnitus, imbalance, and hearing loss in the elderly. Am J Otol. 1986;7(6):476-7. Exclude: Not a primary study. [pmid: 3492920].
She W, Dai Y, Du X, et al. Treatment of subjective tinnitus: A comparative clinical study of intratympanic steroid injection vs. oral carbamazepine. Med Sci Monitor. 2009;15(6):I35-I39. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 19478715].
Shea JJ, Emmett JR, Orchik DJ, et al. Medical treatment of tinnitus. Ann Otol Rhinol Laryngol. 1981;90(6:Pt 1):264-70. Exclude: Not a primary study. [pmid: 7271132].
Shea JJ, Harell M. Management of tinnitus aurium with lidocaine and carbamazepine. Laryngoscope. 1978;88(9:Pt 1):1477-84. Exclude: Case study or series. [pmid: 682804].
Shemen L. Fluoxetine for treatment of tinnitus. Otolaryngol Head Neck Surg. 1998;118(3:Pt 1):421. Exclude: Not a primary study. [pmid: 9527133].
Shiomi Y, Takahashi H, Honjo I, et al. Efficacy of transmeatal low power laser irradiation on tinnitus: A preliminary report. Auris Nasus Larynx. 1997;24(1):39-42. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9148726].
Shulman A, Ballantyne JC, Shea J. Section 1: Tinnitus masking. J Laryngol Otol. 1983;97(Suppl 9):249-56. Exclude: Not a primary study.
Shulman A, Goldstein B. Intratympanic drug therapy with steroids for tinnitus control: A preliminary report. Int Tinnitus J. 2000;6(1):10-20. Exclude: Case study or series. [pmid: 14689612].
Shulman A, Strashun AM, Goldstein BA. GABAA-benzodiazepine-chloride receptor-targeted therapy for tinnitus control: Preliminary report. Int Tinnitus J. 2002;8(1):30-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 14763233].
Shulman A. Clinical classification of subjective idiopathic tinnitus. J Laryngol Otol Suppl. 1981;(4):102-6. Exclude: Not a primary study. [pmid: 6946157].
Shulman A. External electrical stimulation in tinnitus control. Am J Otol. 1985;6(1):110-5. Exclude: Case study or series. [pmid: 3872077].
Shulman A. External electrical stimulation. Tinnitus suppression-hearing preliminary results. J Laryngol Otol. 1983;97(Suppl 9):141-4. Exclude: Case study or series. [pmid: 6600776].
Shulman A. Gabapentin and tinnitus relief. Int Tinnitus J. 2008;14(1):1-5. Exclude: Not a primary study. [pmid: 18616079].
Shulman A. Medical audiological evaluation of the tinnitus patient. Semin Hear. 1987;8(1):7-14. Exclude: Not a primary study.
Shulman A. Secondary endolymphatic hydrops--tinnitus. Otolaryngol Head Neck Surg. 1991;104(1):146-7. Exclude: Article not available. [pmid: 1900621].
Shulman A. Tinnitology, tinnitogenesis, nuclear medicine, and tinnitus patients. Int Tinnitus J. 1998;4(2):102-8. Exclude: Not a primary study. [pmid: 10753396].
Shulman A. Tinnitus suppression. Laryngoscope. 1987;97(9):1109-10. Exclude: Not a primary study. [pmid: 3498105].
Shulman A. Vasodilator-antihistamine therapy and tinnitus control. J Laryngol Otol Suppl. 1981;(4):123-9. Exclude: Case study or series. [pmid: 6117599].
Silverstein H, Choo D, Rosenberg SI, et al. Intratympanic steroid treatment of inner ear disease and tinnitus (preliminary report). Ear Nose Throat J. 1996;75(8):468-71. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 8828271].
Silverstein H, Isaacson JE, Olds MJ, et al. Dexamethasone inner ear perfusion for the treatment of Meniere’s disease: A prospective, randomized, double-blind, crossover trial. Am J Otol. 1998;19(2):196-201. Exclude: Non-randomized head-to-head. [pmid: 9520056].
Simpson JJ, Donaldson I, Davies WE. Use of homeopathy in the treatment of tinnitus. Br J Audiol. 1998;32(4):227-33. Exclude: Non-randomized head-to-head. [pmid: 9923984].
Simpson JJ, Donaldson I, Gilbert AM, et al. The assessment of lamotrigine, an anti-epileptic drug, in the treatment of tinnitus. Br J Audiol. 1997;31(2):118. Exclude: Not a primary study.
Simpson JJ, Gilbert AM, Weiner GM, et al. The assessment of lamotrigine, an antiepileptic drug, in the treatment of tinnitus. Am J Otol. 1999;20(5):627-31. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10503585].
Singhal S, Sharma SC, Singhal KC. Adverse reactions to gentamycin in patients with ear, nose or throat infections. Indian J Physiol Pharmacol. 1992;36(3):189-92. Exclude: Tinnitus is somatic. [pmid: 1473850].
Sirimanna T, Stephens D. Coping with tinnitus. Practitioner. 1992;236(1518):821-6. Exclude: Not a primary study. [pmid: 1461881].
Sismanis A. Tinnitus. Advances in evaluation and management. Otolaryngol Clin North Am. 2003;36(2):xi-xii. Exclude: Not a primary study. [pmid: 12856292].
Slater R. On helping people with tinnitus to help themselves. Br J Audiol. 1987;21(2):87-90. Exclude: Not a primary study. [pmid: 3594018].
Smith JA, Mennemeier M, Bartel T, et al. Repetitive transcranial magnetic stimulation for tinnitus: A pilot study. Laryngoscope. 2007;117(3):529-34. Exclude: Case study or series. [pmid: 17334317].
Smith PA, Parr VM, Lutman ME, et al. Comparative study of four noise spectra as potential tinnitus maskers. Br J Audiol. 1991;25(1):25-34. Exclude: Non-randomized head-to-head. [pmid: 2012900].
Sobhy OA, Koutb AR, Abdel-Baki FA, et al. Evaluation of aural manifestations in temporo-mandibular joint dysfunction. Clin Otolaryngol Allied Sci. 2004;29(4):382-5. Exclude: Non-randomized head-to-head. [pmid: 15270827].
Sobrinho PG, Oliveira CA, Venosa AR. Long-term follow-up of tinnitus in patients with otosclerosis after stapes surgery. Int Tinnitus J. 2004;10(2):197-201. Exclude: Tinnitus is somatic. [pmid: 15732523].
Sockalingam R, Dunphy L, Nam K-E, et al. Effectiveness of frequency-matched masking and residual inhibition in tinnitus therapy: A preliminary study. Audiol Med. 2007;5(2):92-102. Exclude: Insufficient detail of outcome data/not extractable.
Sockalingam R, Gulliford K, Gulliver M, et al. Effectiveness of frequency-matched masking and residual inhibition in tinnitus therapy. Asia Pac J Speech Lang Hear. 2006;10(2):87-103. Exclude: Insufficient detail of outcome data/not extractable.
Souliere CR Jr, Kileny PR, Zwolan TA, et al. Tinnitus suppression following cochlear implantation. A multifactorial investigation. Arch Otolaryngol Head Neck Surg. 1992;118(12):1291-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 1449687].
Sparano A, Leonetti JP, Marzo S, et al. Effects of stapedectomy on tinnitus in patients with otosclerosis. Int Tinnitus J. 2004;10(1):73-7. Exclude: Tinnitus is somatic. [pmid: 15379354].
Spitzer JB, Goldstein BA, Salzbrenner LG, et al. Effect of tinnitus masker noise on speech discrimination in quiet and two noise backgrounds. Scand Audiol. 1983;12(3):197-200. Exclude: Non-randomized head-to-head. [pmid: 6648316].
Stacey JS. Apparent total control of severe bilateral tinnitus by masking, using hearing aids. Br J Audiol. 1980;14(2):59-60. Exclude: Case study or series. [pmid: 7388189].
Staecker H. Tinnitus evaluation and treatment: Assessment of quality of life indicators. Acta Otorhinolaryngol Belgica. 2002;56(4):355-6. Exclude: Not a primary study. [pmid: 12674089].
Stanaway RG, Morley T, Anstis SM. Tinnitus not a reference signal in judgments of absolute pitch. Q J Exp Psychol. 1970;22(2):230-8. Exclude: Case study or series. [pmid: 5431399].
Steenerson RL, Cronin GW. Treatment of tinnitus with electrical stimulation. Otolaryngol Head Neck Surg. 1999;121(5):511-3. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10547461].
Steiger JR, Hamill TA. A proposed clinical pathway for tinnitus evaluation and management. Hear J. 2004;57(7):26-8. Exclude: Not a primary study.
Steigerwald DP, Verne SV, Young D. A retrospective evaluation of the impact of temporomandibular joint arthroscopy on the symptoms of headache, neck pain, shoulder pain, dizziness, and tinnitus. Cranio. 1996;14(1):46-54. Exclude: Non-randomized head-to-head. [pmid: 9086876].
Steinmetz LG, Zeigelboim BS, Lacerda AB, et al. The characteristics of tinnitus in workers exposed to noise. Revista Brasileira de Otorrinolaringologia. 2009;75(1):7-14. Exclude: Case study or series. [pmid: 19488554].
Stephens D, Jaworski A, Kerr P, et al. Use of patient-specific estimates in patient evaluation and rehabilitation. Scand Audiol Suppl. 1998;27(49):61-8. Exclude: Not a primary study. [pmid: 10209779].
Stephens SD, Corcoran AL. A controlled study of tinnitus masking. Br J Audiol. 1985;19(2):159-67. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3896354].
Stevinson C. Negative trial of ginkgo for tinnitus. Focus Alt Complement Ther. 2001;6(2):121. Exclude: Not a primary study.
Stidham KR, Solomon PH, Roberson JB. Evaluation of botulinum toxin A in treatment of tinnitus. Otolaryngol Head Neck Surg. 2005;132(6):883-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 15944559].
Stiegler P, Matzi V, Lipp C, et al. Hyperbaric oxygen (HBO2) in tinnitus: influence of psychological factors on treatment results?. Undersea Hyperb Med. 2006;33(6):429-37. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17274312].
Stoney PJ, Callaghan DE, Walker FS, et al. A controlled trial of azapropazone in tinnitus. Br J Audiol. 1991;25(6):415-7. Exclude: Non-randomized head-to-head. [pmid: 1773202].
Stuerz K, Lafenthaler M, Pfaffenberger N, et al. Body image and body concept in patients with chronic tinnitus. Eur Arch Otorhinolaryngol. 2009;266(7):961-5. Exclude: Only determined various effects. [pmid: 18941764].
Suchova L. Tinnitus retraining therapy--The experiences in Slovakia. Bratisl Lek Listy. 2005;106(2):79-82. Exclude: Case study or series. [pmid: 16026138].
Sulkowski W, Kowalska S, Lipowczan A, et al. Tinnitus and impulse noise-induced hearing loss in drop-forge operators. Int J Occup Med Environ Health. 1999;12(2):177-82. Exclude: Only about prevalence. [pmid: 10465907].
Sullivan MD, Dobie RA, Sakai CS, et al. Treatment of depressed tinnitus patients with nortriptyline. Ann Otol Rhinol Laryngol. 1989;98(11):867-72. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2817678].
Sullivan MD, Katon W, Dobie R, et al. Disabling tinnitus. Association with affective disorder. Gen Hosp Psychiatry. 1988;10(4):285-91. Exclude: Only determined various effects. [pmid: 3417130].
Surr RK, Kolb JA, Cord MT, et al. Tinnitus Handicap Inventory (THI) as a hearing aid outcome measure. J Am Acad Audiol. 1999;10(9):489-95. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 10522622].
Sutbas A, Yetiser S, Satar B, et al. Low-cholesterol diet and antilipid therapy in managing tinnitus and hearing loss in patients with noise-induced hearing loss and hyperlipidemia. Int Tinnitus J. 2007;13(2):143-9. Exclude: Non-randomized head-to-head. [pmid: 18229794].
Sweetow R. Counseling the patient with tinnitus. Arch Otolaryngol. 1985;111(5):283-4. Exclude: Not a primary study. [pmid: 3985848].
Sweetow RW, Mraz NR. Providing audiology services to tinnitus patients. Audiol Today. 2004;16(1):33-5. Exclude: Article not available.
Sweetow RW, Sabes JH. Effects of acoustical stimuli delivered through hearing aids on tinnitus. J Am Acad Audiol. 2010;21(7):461-73. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20807482].
Sweetow RW. Comprehensive tinnitus patient management. Semin Hear. 1987;8(1):71-4. Exclude: Not a primary study.
Sziklai I, Komora V, Ribari O. Double-blind study on the effectiveness of a bioflavonoid in the control of tinnitus in otosclerosis. Acta Chir Hung. 1992;33(1–2):101-7. Exclude: Tinnitus is somatic. [pmid: 1343452].
Sziklai I, Szilvassy J, Szilvassy Z. Tinnitus control by dopamine agonist pramipexole in presbycusis patients: A randomized, placebo-controlled, double-blind study. Laryngoscope. 2011;121(4):888-93. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21433025].
Szymanski M, Golabek W, Mills R. Effect of stapedectomy on subjective tinnitus. J Laryngol Otol. 2003;117(4):261-4. Exclude: Case study or series. [pmid: 12816213].
Tan J, Tange RA, Dreschler WA, et al. Long-term effect of hyperbaric oxygenation treatment on chronic distressing tinnitus. Scand Audiol. 1999;28(2):91-6. Exclude: Case study or series. [pmid: 10384896].
Tauber S, Schorn K, Beyer W, et al. Transmeatal cochlear laser (TCL) treatment of cochlear dysfunction: A feasibility study for chronic tinnitus. Lasers Med Sci. 2003;18(3):154-61. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 14505199].
Terry AM, Jones DM, Davis BR, et al. Parametric studies of tinnitus masking and residual inhibition. Br J Audiol. 1983;17(4):245-56. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 6667357].
Terry AM, Jones DM. Preference for potential tinnitus maskers: Results from annoyance ratings. Br J Audiol. 1986;20(4):277-97. Exclude: Non-randomized head-to-head. [pmid: 3790773].
Test T, Canfi A, Eyal A, et al. The influence of hearing impairment on sleep quality among workers exposed to harmful noise. Sleep. 2011;34(1):25-30. Exclude: Only determined various effects. [pmid: 21203368].
Tewfik S. Phonocephalography. An objective diagnosis of tinnitus. J Laryngol Otol. 1974;88(9):869-75. Exclude: Tinnitus is somatic. [pmid: 4430868].
The treatment of tinnitus. Clin Otolaryngol Allied Sci. 1980;5(1):1-2. Exclude: Not a primary study. [pmid: 7363488].
Thedinger BS, Karlsen E, Schack SH. Treatment of tinnitus with electrical stimulation: An evaluation of the Audimax Theraband. Laryngoscope. 1987;97(1):33-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3491942].
Thomas M, Laurell G, Lundeberg T. Acupuncture for the alleviation of tinnitus. Laryngoscope. 1988;98(6:Pt 1):664-7. Exclude: Case study or series. [pmid: 3374243].
Thomas M, Laurell G, Lundeberg T. Vibratory stimulation as a treatment alternative in patients with tinnitus. Ear Nose Throat J. 817;68(11):810-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2693064].
Ting SKS, Chan YM, Cheong PWT, et al. Short duration repetitive transcranial magnetic stimulation for tinnitus treatment: A prospective Asian study. Clin Neurol Neurosurg. 2011;113(7):556-8. Exclude: Non-randomized head-to-head. [pmid: 21507564].
Tinnitus: Treatment methods and results. J Laryngol Otol Suppl. 1984;9:247-318. Exclude: Article not available. [pmid: 6440940].
Tonkin JP. Tinnitus. Clinical approaches to management. Curr Ther. 1985;26(1):37-40. Exclude: Not a primary study.
Trotter MI, Donaldson I. Hearing aids and tinnitus therapy: A 25-year experience. J Laryngol Otol. 2008;122(10):1052-6. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18353195].
Tullberg M, Ernberg M. Long-term effect on tinnitus by treatment of temporomandibular disorders: A two-year follow-up by questionnaire. Acta Odontol Scand. 2006;64(2):89-96. Exclude: Non-randomized head-to-head. [pmid: 16546850].
Turner JS Jr. Treatment of hearing loss, ear pain, and tinnitus in older patients. Geriatrics. 116;37(8):107-11. Exclude: Not a primary study. [pmid: 7095424].
Tyler RS, Babin RW, Niebuhr DP. Some observations on the masking and post-masking effects of tinnitus. J Laryngol Otol. 1983;97(Suppl 9):150-6. Exclude: Not a primary study.
Tyler RS, Bentler RA. Tinnitus maskers and hearing aids for tinnitus. Semin Hear. 1987;8(1):49-61. Exclude: Not a primary study.
Tyler RS. Tinnitus in the profoundly hearing-impaired and the effects of cochlear implants. Ann Otol Rhinol Laryngol Suppl. 1995;165:25-30. Exclude: Case study or series. [pmid: 7717631].
Uri N, Doweck I, Cohen-Kerem R, et al. Acyclovir in the treatment of idiopathic sudden sensorineural hearing loss. Otolaryngol Head Neck Surg. 2003;128(4):544-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 12707659].
Van de Heyning P, Vermeire K, Diebl M, et al. Incapacitating unilateral tinnitus in single-sided deafness treated by cochlear implantation. Ann Otol Rhinol Laryngol. 2008;117(9):645-52. Exclude: Non-randomized head-to-head. [pmid: 18834065].
Van Deelen GW, Huizing EH. Use of a diuretic (Dyazide) in the treatment of Meniere’s disease. A double-blind cross-over placebo-controlled study. ORL. 1986;48(5):287-92. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3537899].
Van Deelen GW, Hulk J, Huizing EH. The use of the underpressure chamber in the treatment of patients with Meniere’s disease. J Laryngol Otol. 1987;101(3):229-35. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3572228].
Vanneste S, Figueiredo R, De RD. Treatment of tinnitus with cyclobenzaprine: An open-label study. Int J Clin Pharmacol Ther. 2012;50(5):338-44. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 22541838].
Vanneste S, Plazier M, Ost J, et al. Bilateral dorsolateral prefrontal cortex modulation for tinnitus by transcranial direct current stimulation: A preliminary clinical study. Exp Brain Res. 2010;202(4):779-85. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20186404].
Vanneste S, Plazier MP, et al. Repetitive transcranial magnetic stimulation frequency dependent tinnitus improvement by double cone coil prefrontal stimulation. J Neurol Neurosurg Psychiatry. 2011;82(10):1160-4. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21429905].
Vanneste S, Plazier M, Van de Heyning P, et al. Transcutaneous electrical nerve stimulation (TENS) of upper cervical nerve (C2) for the treatment of somatic tinnitus. Exp Brain Res. 2010;204(2):283-7. Exclude: Non-randomized head-to-head. [pmid: 20505927].
Vanneste S, Plazier M, van der Loo E, et al. Burst transcranial magnetic stimulation: Which tinnitus characteristics influence the amount of transient tinnitus suppression?. Eur J Neurol. 2010;17(9):1141-7. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 20374277].
Vasama JP, Moller MB, Moller AR. Microvascular decompression of the cochlear nerve in patients with severe tinnitus. Preoperative findings and operative outcome in 22 patients. Neurol Res. 1998;20(3):242-8. Exclude: Case study or series. [pmid: 9583586].
Vermeij P, Hulshof JH, Hilders CGJM, et al. Lidocaine in the treatment of tinnitus. Eur J Pharmacol. 1990;183(3):1021. Exclude: Not a primary study.
Vermeij P, Hulshof JH. Dose finding of tocainide in the treatment of tinnitus. Int J Clin Pharmacol Ther Toxicol. 1986;24(4):207-12. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3086242].
Vermeire K, Heyndrickx K, De RD, et al. Phase-shift tinnitus treatment: An open prospective clinical trial. B-ENT. 2007;3(Suppl 7):65-9. Exclude: Non-randomized head-to-head. [pmid: 18225610].
Vermeire K, Van de Heyning P. Binaural hearing after cochlear implantation in subjects with unilateral sensorineural deafness and tinnitus. Audiol Neuro Otol. 2009;14(3):163-71. Exclude: Non-randomized head-to-head. [pmid: 19005250].
Vernon J, Press L, McLaughlin T. Magnetic resonance imaging and tinnitus. Otolaryngol Head Neck Surg. 1996;115(6):587-8. Exclude: Not a primary study. [pmid: 8969772].
Vernon J, Schleuning A. Tinnitus: A new management. Laryngoscope. 1978;88(3):413-9. Exclude: Not a primary study. [pmid: 628295].
Vernon J. Use of electricity to suppress tinnitus. Semin Hear. 1987;8(1):29-48. Exclude: Not a primary study.
Vernon JA, Fenwick JA. Attempts to suppress tinnitus with transcutaneous electrical stimulation. Otolaryngol Head Neck Surg. 1985;93(3):385-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3927235].
Vernon JA, Press LS. Characteristics of tinnitus induced by head injury. Arch Otolaryngol Head Neck Surg. 1994;120(5):547-51. Exclude: Non-randomized head-to-head. [pmid: 8172707].
Vesterager V. Combined psychological and prosthetic management of tinnitus: A cross-sectional study of patients with severe tinnitus. Br J Audiol. 1994;28(1):1-11. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7987267].
Vierstraete K, Debruyne F, Vantrappen G, et al. Tinnitus maskers in the treatment of tinnitus. The MICROTEK 321Q. Acta Otorhinolaryngol Belgica. 1996;50(3):211-20. Exclude: Case study or series. [pmid: 8888905].
von Wedel H, Calero L, Walger M, et al. Soft-laser/Ginkgo therapy in chronic tinnitus. A placebo-controlled study. Adv Otorhinolaryngol. 1995;49:105-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 7653340].
von Wedel H, von Wedel UC, Zorowka P. Tinnitus diagnosis and therapy in the aged. Acta Otolaryngol Suppl. 1990;476:195-201. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 2087963].
Voroba B. Tinnitus research frontiers. Acta Phoniatrica Latina. 1981;3(Suppl):9-17. Exclude: Not a primary study.
Waddell A, Canter R. Tinnitus Clin Evid. 2002;(7):481-9. Exclude: Article not available. [pmid: 12230674].
Walsh WM, Gerley PP. Thermal biofeedback and the treatment of tinnitus. Laryngoscope. 1985;95(8):987-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3894844].
Wang K, Bugge J, Bugge S. A randomised, placebo-controlled trial of manual and electrical acupuncture for the treatment of tinnitus. Complement Ther Med. 2010;18(6):249-55. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 21130361].
Wang L, Wu P, Ju YL. Observation on the effect of acupoint Iinjection for sensorineural hearing loss and tinnitus. J Tradit Chin Med. 2008;49(1):47-9. Exclude: Article not available.
Ward LM, Baumann M. Measuring tinnitus loudness using constrained psychophysical scaling. Am J Audiol. 2009;18(2):119-28. Exclude: Non-randomized head-to-head. [pmid: 19638478].
Ward WD. General auditory effects of noise. Otolaryngol Clin North Am. 1979;12(3):473-92. Exclude: Not a primary study. [pmid: 471497].
Weiler EW, Brill K, Tachiki KH, et al. Neurofeedback and quantitative electroencephalography. Int Tinnitus J. 2002;8(2):87-93. Exclude: Case study or series. [pmid: 14763216].
Weise C, Heinecke K, Rief W. Stability of physiological variables in chronic tinnitus sufferers. Appl Psychophysiol Biofeedback. 2008;33(3):149-59. Exclude: Only determined various effects. [pmid: 18600443].
Welch D, Dawes PJ. Personality and perception of tinnitus. Ear Hear. 2008;29(5):684-92. Exclude: Non-randomized head-to-head. [pmid: 18596645].
West PDB. Effective treatment for tinnitus: Audit of a district general hospital service. J Audiol Med. 1999;8(2):92-100. Exclude: Insufficient detail of outcome data/not extractable.
Westerlaken BO, de Kleine E, van der Laan B, et al. The treatment of idiopathic sudden sensorineural hearing loss using pulse therapy: A prospective, randomized, double-blind clinical trial. Laryngoscope. 2007;117(4):684-90. Exclude: Non-randomized head-to-head. [pmid: 17415139].
Westin V, Hayes SC, Andersson G. Is it the sound or your relationship to it? The role of acceptance in predicting tinnitus impact. Behav Res Ther. 2008;46(12):1259-65. Exclude: Only determined various effects. [pmid: 18926522].
Westin V, Ostergren R, Andersson G. The effects of acceptance versus thought suppression for dealing with the intrusiveness of tinnitus. Int J Audiol. 2008;47:112-8. Exclude: Non-randomized head-to-head. [pmid: 19012119].
White TP, Hoffman SR, Gale EN. Psychophysiological therapy for tinnitus. Ear Hear. 1986;7(6):397-9. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 3539680].
Wilmot TJ, Menon GN. Betahistine in Meniere’s disease. J Laryngol Otol. 1976;90(9):833-40. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 787460].
Wilson PH, Henry J, Bowen M, et al. Tinnitus reaction questionnaire: Psychometric properties of a measure of distress associated with tinnitus. J Speech Hear Res. 1991;34(1):197-201. Exclude: Not a primary study. [pmid: 2008074].
Wilson PH, Henry JL. Psychological approaches in the management of tinnitus. Aust J Otolaryngol. 1993;1(4):296-302. Exclude: Not a primary study.
Wilson PH, Henry JL. Tinnitus cognitions questionnaire: Development and psychometric properties of a measure of dysfunctional cognitions associated with tinnitus. Int Tinnitus J. 1998;4(1):23-30. Exclude: Non-randomized head-to-head. [pmid: 10753381].
Wise K, Rief W, Goebel G. Meeting the expectations of chronic tinnitus patients: Comparison of a structured group therapy program for tinnitus management with a problem-solving group. J Psychosom Res. 1998;44(6):681-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 9678749].
Witsell DL, Hannley MT, Stinnet S, et al. Treatment of tinnitus with gabapentin: A pilot study. Otol Neurotol. 2007;28(1):11-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17106432].
Wood KA, Webb WL Jr, Orchik DJ, et al. Intractable tinnitus: Psychiatric aspects of treatment. Psychosomatics. 565;24(6):559-61. Exclude: Case study or series. [pmid: 6878604].
Wright EF, Bifano SL. Tinnitus improvement through TMD therapy. J Am Dent Assoc. 1997;128(10):1424-32. Exclude: Non-randomized head-to-head. [pmid: 9332144].
Yamada Y, Tomita H. Influences on taste in the area of chorda tympani nerve after transtympanic injection of local anesthetic (4% lidocaine). Auris Nasus Larynx. 1989;16:41-6. Exclude: Non-randomized head-to-head. [pmid: 2604615].
Yanick J. Dietary and lifestyle influences on cochlear disorders and biochemical status: A 12-month study. J Appl Nutr. 1988;40(2):75-84. Exclude: Insufficient detail of outcome data/not extractable.
Yetiser S, Kertmen M. Intratympanic gentamicin in Meniere’s disease: The impact on tinnitus. Int J Audiol. 2002;41(6):363-70. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 12353609].
Yetiser S, Tosun F, Satar B, et al. The role of zinc in management of tinnitus. Auris Nasus Larynx. 2002;29(4):329-33. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 12393036].
Ylikoski J, Mrena R, Makitie A, et al. Hyperbaric oxygen therapy seems to enhance recovery from acute acoustic trauma. Acta Otolaryngol. 2008;128(10):1110-5. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 18607951].
Yonehara E, Mezzalira R, Porto PR, et al. Can cochlear implants decrease tinnitus?. Int Tinnitus J. 2006;12(2):172-4. Exclude: Case study or series. [pmid: 17260883].
Young IM, Lowry LD. Incurrence and alterations in contralateral tinnitus following monaural exposure to a pure tone. J Acoust Soc Am. 1983;73(6):2219-21. Exclude: Case study or series. [pmid: 6875103].
Zagolski O. Management of tinnitus in patients with presbycusis. Int Tinnitus J. 2006;12(2):175-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 17260884].
Zenner HP, De Maddalena H. Validity and reliability study of three tinnitus self-assessment scales: Loudness, annoyance and change. Acta Otolaryngol. 2005;125(11):1184-8. Exclude: Insufficient detail of outcome data/not extractable. [pmid: 16353397].
Zenner HP. A totally implantable drug delivery system for local therapy of tinnitus. Int Tinnitus J. 2001;7(1):40. Exclude: Article not available. [pmid: 14964954].
Zhou F, Wu P, Wang L, et al. The NGF point-injection for treatment of the sound-perceiving nerve deafness and tinnitus in 68 cases. J Tradit Chin Med. 2009;29(1):39-42. Exclude: Case study or series. [pmid: 19514187].
Zhou Y, Wei W. Clinical experience in application of the point zhongzhu. J Tradit Chin Med. 2002;22(4):294-5. Exclude: Case study or series. [pmid: 16579098].
Zimbabwean people with head noises are offered help. Cent Afr J Med. 1998;44(11):296. Exclude: Not a primary study. [pmid: 10189754].
Zoger S, Svedlund J, Holgers KM. Relationship between tinnitus severity and psychiatric disorders. Psychosomatics. 2006;47(4):282-8. Exclude: Only about prevalence. [pmid: 16844885].