# Data Extraction Forms

Title & Abstract Screening Form—Level 1

Title & Abstract Level 1 Screening Form Help Sheet

Title & Abstract Screening Form—Level 2

Title & Abstract Level 2 Screening Form Help Sheet

Full Text Screen

Full Text Screening Form Help Sheet

Data Extraction

Modified Jadad

TNT Outcomes Continuous