# Search Strategy

## Search Strategy: Tinnitus

### Medline-OVID

1946–June 13 2012

1 Tinnitus/or tinnitus.ti.
2 animals/not humans/
3 1 not 2
4 limit 3 to english language
5 limit 4 to (case reports or comment or editorial or in vitro or interview or letter or newspaper article or webcasts)
7 4 not 5

### Embase-OVID

1980–June 13 2012

1. Tinnitus/or tinnitus.ti.
2. limit 1 to english language
3. limit 2 to (book or book series or conference abstract or conference paper or editorial or letter or note)
4. 2 not 3
5. limit 4 to human

### Cochrane Controlled Trials Registry-OVID

June 13 2012

1. Tinnitus/or tinnitus.ti.

### PsycINFO-OVID

1967–June 13 2012

1. Tinnitus/or tinnitus.ti.
2. animals/not humans/
3. 1 not 2
4. limit 3 to english language
5. limit 4 to (abstract collection or chapter or “column/opinion” or “comment/reply” or dissertation or editorial or encyclopedia entry or letter or obituary or poetry or review-book or review-media or review-software & other)
6. 4 not 5

### AMED-OVID

1985–June 13 2012

1. Tinnitus/or tinnitus.ti.
2. animals/not humans/
3. 1 not 2
4. limit 3 to english language