# Results

## Introduction

In this section, the reader will find our literature search results, including information about how many abstracts we identified and why we excluded most abstracts from this report. This is followed by the key findings for Key Question 1 (KQ1; incarceration setting) organized by treatment type (pharmacologic therapy, psychological therapy, and dual disorder treatments); a description of the included studies for KQ1, including basic study design information, inclusion/exclusion criteria, outcomes reported, a description of the instruments used to measure each outcome; a more in-depth description of the study findings; and a description of individual study risk-of-bias assessments, strength-of-evidence grades for the body of evidence, and applicability; all organized by the type of treatment studied. All of the same information is then provided for Key Question 2 (KQ2; incarceration to community transitions), organized by treatment type.

## Literature Search Results

Our searches of the literature identified 4,587 potentially relevant articles, and we excluded 811 of these at the title level (Figure 2). At the abstract level, we excluded another 3,214 articles typically because they were irrelevant to our Key Questions (1,737 publications); were background, review, commentary, or protocol articles (621 publications); were not comparative trials (500 publications); or were not conducted within a country of interest to this report (102 publications). At the full-length article review, we further excluded another 543 articles, typically because they were background, review, commentary, or protocol articles (302 publications); were not comparative trials (99 publications); or the study populations were not primarily serious mental illness (SMI; 60 publications).

Figure 2 Literature flow diagram

KQ = Key Question; SMI = serious mental illness

Figure 2 is a literature flow diagram. In the top left corner, there is a box (Box 1) showing we identified 4,587 potentially relevant articles. Just below that is a second box (Box 2) in which we show that 4,587 titles were reviewed. To the right of Box 2 is a third box (Box 3), showing we excluded 811 of these at the title level. On that far-left side, under Box 2 is a fourth box (Box 4), which shows that we reviewed 3,776 abstracts. To the right of that is a fifth box. In Box 5 we show that 3,214 of these abstracts were excluded. To the right again, in Box 6, we list the reason articles were excluded at the abstract level. The reasons were as follows: 1,737 (off-topic), 621 (background), 500 (not a comparative trial), 102 (not a country of interest), 64 (not SMI offenders), 51 (not a criminal justice setting of interest), 50 (did not assess the efficacy of an intervention), 40 (fewer than 5 patients per study group), 33 (study of children), 12 (duplicate reports), 3 (not a full length article), and 1 ( not in the English language). Towards the right bottom of the figure is a seventh box (Box 7) which shows we reviewed 562 full-length articles. To the right, in Box 8, we show that 543 of these full length articles were excluded. In Box 9, on the far right of the figure we list the reasons for excluding full-length articles. The most common reasons were because they were background, review, commentary, or protocol articles (302 publications); were not comparative trials (99 publications); or the study populations were not primarily SMI (60 publications). At the very bottom, right corner of the figure is Box 10. Box 10 shows that 19 publications describing16 unique studies made up the evidence base for this review. Twelve articles describing nine unique studies addressed KQ1 (interventions delivered within an incarceration setting), and seven studies addressed KQ2 (interventions provided during transition from incarceration to a community setting).

The remaining 19 publications describing 16 unique studies made up the evidence base for this review. Twelve articles describing nine unique studies addressed KQ1 (interventions delivered within an incarceration setting), and seven studies addressed KQ2 (interventions provided during transition from incarceration to a community setting).

## KQ1 Interventions Applied Within Jail, Prison, or Forensic Hospital Settings

KQ1. What is the comparative effectiveness of interventions applied within a jail, prison, or forensic hospital setting for adults with SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a co-occurring alcohol/substance abuse diagnosis?

### Key Points

- Evidence of low strength favored antipsychotics other than clozapine over clozapine for improving psychiatric symptoms in an incarceration setting.
- Evidence was insufficient to draw conclusions about the comparative effectiveness of risperidone with other antipsychotics or of chlorpromazine at a high dosage versus chlorpromazine at a standard dosage in these populations and settings.
- Evidence was insufficient to draw conclusions about the comparative effectiveness of cognitive behavior therapy (CBT) versus treatment as usual or individual supportive therapy.
- Evidence was insufficient to draw conclusions about the comparative effectiveness of modified therapeutic community (MTC) treatment with more standard in-prison mental health and substance abuse services for men and women with dual diagnoses.

### Description of Included Studies

For KQ1, we reviewed studies that evaluated interventions that were provided during incarceration within a jail, prison, or forensic hospital. To be eligible, studies must have covered one or more of the interventions of interest for the settings addressed in KQ1 listed in Table 1 in the background section of this report. The studies must have compared one of the identified interventions with another intervention or to standard of care or treatment as usual. We did not consider studies that compared an intervention with a waitlist control or no treatment group for this question. We also considered whether there was a difference in the comparative effectiveness of interventions based on the setting (i.e., jail, prison, forensic hospital) in which the interventions were provided.

Nine studies published in 12 separate publications met the eligibility criteria for this Key Question. Two of the studies were reported in more than one publication. Three publications reported results on different outcomes for the same patient population.61–63 For this report, we considered those publications to be one study. However, we described the results for all outcomes reported in each of the publications. Another two publications reported the same outcomes for an overlapping patient population but for different time points.64,65

As presented in Table 5, four studies evaluated pharmacologic interventions, three considered psychological therapies, and two evaluated interventions designed to treat inmates who had a dual diagnosis of SMI and substance abuse. Four of the studies were randomized controlled trials (RCTs) and five were nonrandomized comparison trials that used a matching strategy to ensure that the patients considered in the study were comparable on key baseline characteristics such as age, diagnosis, treatment history, and criminal justice history. The number of patients enrolled in the studies ranged from 10 to 468.

Table 5 Characteristics of included studies for Key Question 1

Reference | Number of Patients | Study Design | Treatment | Comparator | Setting
Rees-Jones et al., 2012^66^ | 121 | Nonrandomized comparative trial | Cognitive skills training: Reasoning & Rehabilitation | Treatment as usual | Forensic hospital
Cullen et al., 2011^67^ | 84 | Multisite randomized control trial | Cognitive skills training: Reasoning & Rehabilitation | Treatment as usual | Medium secure forensic units
Balbuena et al., 2010^68^ | 98 | Nonrandomized comparative trial | Clozapine | Other antipsychotics | Forensic hospital
Martin et al., 2008^69^ | 73 | Nonrandomized comparative trial | Clozapine | Other antipsychotics | Acute unit of a forensic hospital
J. Sacks et al., 2008^64^ & J. Sacks et al. 2012^65^ | 468 | Randomized controlled trial | Modified therapeutic community | Intensive outpatient program | Medium secure prison
S. Sacks et al., 2004^61^ & Sullivan et al., 2007a62 & Sullivan et al., 2007b63 | 139 | Randomized controlled trial | Modified therapeutic community with or without aftercare | Standard mental health interventions | Maximum security forensic prison
Tavernor et al., 2000^70^ | 50 | Nonrandomized comparative trial | High-dose chlorpromazine | Standard-dose chlorpromazine | Maximum security hospital for patients considered to be a “grave and immediate danger”
Beck et al., 1997^71^ | 20 | Nonrandomized comparative trial | Risperidone | Traditional neuroleptics | Maximum security unit of a State mental hospital
Wilson, 1990^72^ | 10 | Randomized controlled trial | Group cognitive therapy | Individual supportive therapy | Maximum security prison

Notes: J. Sacks et al. 2008 and J. Sacks et al. 2012 report on overlapping patient populations. The J. Sacks et al. 2012 publication included 154 additional subjects and longer-term followup. We consider these two publications a single study. Because the quality of data reporting was superior in the J. Sacks et al. 2008 publication, we rely mainly on that report, but supplement it when possible with information from the 2012 publication.

S. Sacks 2004, Sullivan 2007a, and Sullivan 2007b all report different outcomes for the same patient population. Because these publications report on the same patient population, we consider it a single study.

See Table 6 for details on the types of patients enrolled and excluded for each trial. Two trials required a diagnosis of psychosis, one required depression, three did not clearly specify psychiatric diagnosis for eligibility, and two required both a psychiatric and substance abuse diagnosis for study entry.

Table 6 Participant inclusion and exclusion criteria for studies addressing Key Question 1

Types of Therapies | Study | Participant Inclusion Criteria (as described in article) | Participant Exclusion Criteria (as described in article)
Pharmacologic therapies | Balbuena et al., 2010^68^ | The clozapine group included all patients with psychosis who were treated with clozapine for a minimum of 6 weeks since facility opened in 1978. The nonclozapine group included matched patients with psychosis who were never treated with clozapine but were on 1 or more antipsychotic medications for a minimum of 6 weeks during the same period. All patients who met DSM-IV criteria for psychosis or other related disorders identified through review of clinical records by 2 research psychiatrists. | Did not meet DSM-IV criteria for psychosis or related disorders.
Pharmacologic therapies | Martin et al., 2008^69^ | Patients admitted to the forensic acute admissions ward between 1999 and 2004 | Not reported
Pharmacologic therapies | Tavernor et al., 2000^70^ | Not reported | Not reported
Pharmacologic therapies | Beck et al., 1997^71^ | Not reported | Not reported
Psychological therapies | Rees-Jones et al., 2012^66^ | Males 18–65 years of age detained under the UK Mental Health Act at 10 secure forensic facilities. Inmates must have had current diagnosis or history of severe mental illness (schizophrenia, schizoaffective disorder, or bipolar disorder), a history of violent or antisocial behavior, no previous treatment with Reasoning & Rehabilitation or any similar treatments, absence of a learning disability, and proficiency in the English language. | Participants were excluded from the study if they were mentally unstable or posed a risk of violence to the research team.
Psychological therapies | Cullen et al., 2011^67^ | Inmates were included if they met the following criteria: (1) a primary clinical diagnosis of psychotic disorder, (2) a history of violent behavior leading to current admission, (3) not having participated in Reasoning & Rehabilitation or treatment, (4) not actively psychotic, (5) absence of significant cognitive impairment, and (6) proficiency in English language sufficient to allow participation in the program. | Not reported
Psychological therapies | Wilson, 1990^72^ | Inmates were included if they met the following criteria: (1) self-reported depression of not less than 5 weeks, (2) a structured interview and judgment by a trained interviewer (author) that depression was a major presenting psychopathology, (3) Beck Depression Inventory scores of not less than 13, (4) not currently receiving medication or other treatment, and (5) willingness to complete treatment and assessment instruments. | Not reported
Dual disorder treatment | J. Sacks et al., 2008^64,65^ a | Participants must have had the following: (1) at least 6 months (and no more than 24 months) remaining until parole eligibility, (2) a Colorado Department of Corrections Standardized Offender Assessment score of 4 or greater indicative of serious substance abuse problems requiring treatment, and (3) a security risk level classification of minimum, minimum-restricted, or medium to permit participation in treatment. | Not reported
Dual disorder treatment | S. Sacks et al., 2004^61^ b & Sullivan et al., 2007a62 b & Sullivan et al., 2007b63 b | Male inmates with psychiatric disorders and co-occurring substance use disorders | Inmates who represented a clear danger to themselves or others

a These studies report on the same patient population and are not considered independent studies in this report.

b These studies report outcomes on the same patient population and are not considered independent studies in this report.

DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, fourth edition

Table 7 lists the outcomes reported on for each of the studies that addressed KQ1. As per the inclusion criteria for this report, all the studies reported on at least one mental health outcome, with all studies reporting on change in psychiatric or behavioral symptoms. The criminal justice outcomes reported by some of the studies included infractions of prison code, recidivism, and reincarceration. Other outcomes reported by some of the studies included substance or alcohol use, time to relapse, dangerousness to others, mental health services use, and adherence to treatment. Only two of the studies, each evaluating pharmacological therapies, reported on adverse events.

Table 7 Included studies and outcomes for Key Question 1

Reference | Independent Functioning | Psychiatric Symptoms | Substance or Alcohol Use | Time to Relapse | Dangerousness to Others | Infractions of Prison Code | Recidivism | Reincarceration | Adverse Events | Mental Health Service Use^*^ | Adherence to Treatment^*^
Rees-Jones et al., 2012^66^ | | ✓
Cullen et al., 2011^67^ | | ✓
Balbuena et al., 2010^68^ | ✓ | ✓ | | | | ✓ | | | | | ✓
Martin et al., 2008^69^ | | ✓ | | | | | | | ✓
J. Sacks et al., 2008^64,65^ a | | ✓ | ✓ | | | | ✓ | ✓ | | ✓
Sullivan et al., 2007a62 b | | | ✓ | ✓
Sullivan et al., 2007b63 b | | ✓ | | | | | | | | ✓
S. Sacks et al., 2004^61^ b | | | | | | | ✓ | ✓
Tavernor et al., 2000^70^ | | ✓ | | | | | | | ✓ | | ✓
Beck et al., 1997^71^ | | ✓ | | | ✓
Wilson, 1990^72^ | | ✓

* Intermediate outcomes.

a These studies report on overlapping patient populations and are not considered independent studies in this report.

b These studies report outcomes on the same patient population and are not considered independent studies in this report.

In most of the studies, psychiatric or behavioral symptoms were measured using a variety of observational or self-reported instruments. The most common instruments used across studies were the Beck Depression Inventory (BDI, 3 studies), the Brief Psychiatric Rating Scale (BPRS, 2 studies), and the Brief Symptom Inventory (BSI, 2 studies). The Beck Depression Inventory (BDI, BDI-II) is one of the most widely used instruments for measuring depression severity.73

The BDI is a 21-question, multiple-choice, self-report inventory composed of items relating to symptoms of depression such as hopelessness and irritability, cognitions such as guilt or feelings of being punished, as well as physical symptoms such as fatigue, weight loss, and lack of interest in sex. Higher scores on the BDI indicate more severe depressive symptoms.

The BPRS and BSI are designed to measure an array of psychiatric symptoms in a fairly brief amount of time. The BPRS is a one-page, 16- to 18-item scale measuring self-report and patient observation of affective and psychotic symptoms.74 Higher scores on this scale indicate the presence of more symptoms.

The BSI is a 53-item, self-report scale used to measure nine primary symptom dimensions (somatization, obsessive-compulsive behavior, interpersonal sensitivity, depression, anxiety, hostility, phobic anxiety, paranoid ideation, and psychoticism) and three global indices (Global Severity Index, Positive Symptom Distress Index, and Positive Symptom Total).75 The BSI is a shortened version of the SCL-90 (Symptom Check List-90) and is designed to provide a multidimensional symptom measurement in about 10 minutes. Higher scores on both versions of the BSI indicate the presence of more psychiatric symptoms. See Table 8 below for more details.

Table 8 Instruments used to measure psychiatric symptoms for Key Question 1

Reference | Instrument
Rees-Jones et al., 2012^66^ | Maudsley Violence Questionnaire and Locus of Control Scale
Cullen et al., 2011^67^ | Social Problem Solving Inventory
Balbuena et al., 2010^68^ | Brief Psychiatric Symptom Inventory
Martin et al., 2008^69^ | Global Impression Scale
J. Sacks et al., 2008^64,65^ a & J. Sacks et al., 2012^64,65^ a | Beck Depression Inventory, Brief Symptom Inventory, Posttraumatic Symptom Scale
S. Sacks et al., 2004^61^ b & Sullivan et al., 2007a62 b & Sullivan et al., 200b7^63^ b | Beck Depression Inventory, Brief Symptom Inventory, Adult Manifest Anxiety Scale
Tavernor et al., 2000^70^ | Brief Psychiatric Symptom Inventory, Global Assessment Scale, Nurses’ Observation Scale, Social Dysfunction and Aggression Scale
Beck et al., 1997^71^ | Time Sample Behavioral Checklist
Wilson, 1990^72^ | Beck Depression Inventory, Hopelessness Scale, Multiple Affect Adjective Check List, Minnesota Multiphasic Personality Inventory

a These studies report on overlapping patient populations and are not considered independent studies in this report.

b These studies report outcomes on the same patient population and are not considered independent studies in this report.

### Risk-of-Bias Assessment

Our risk-of-bias assessments for the studies that address KQ1 appear in Table D1 of Appendix D. We categorized all trials as medium risk of bias for all reported outcomes. The most common reasons for the designation were that they used subjective outcome measures (psychiatric symptoms, self-reported criminal justice outcomes), failed to blind outcome assessors (either not performed or not reported), and experienced attrition.

### Pharmacologic Therapies

#### Description of Studies

Four studies that addressed KQ1 evaluated the efficacy of pharmacologic therapies for incarcerated individuals with SMI. All four studies were nonrandomized comparison studies that used matching strategies to ensure baseline comparability of the enrolled patients on key characteristics such as diagnosis, functioning, criminal justice history, and age. Only one study was prospectively planned.71 The other three studies were retrospective chart reviews.68–70 The patients in all four studies were incarcerated in forensic hospitals or specialized forensic units.

The studies took place in various locations, with one each taking place in the United States, the United Kingdom, Australia, and Canada. See Table E1 of Appendix E for more information about the general characteristics of the studies.

Two of the studies compared the efficacy of clozapine with the efficacy of other antipsychotics.68,69 The objective of both studies was to examine the suitability of clozapine for forensic patients. Clozapine is often used in treatment-resistant schizophrenia and is known for its antiaggression properties.68 However, its use has been associated with a number of adverse events, including sleepiness, rapid heartbeat, constipation, drooling, weight gain, and orthostatic hypotension.76 More serious adverse events include agranulocytosis, myocarditis, cardiomyopathy, pulmonary embolism, respiratory depression, and seizures. Patients taking clozapine are required to undergo regular blood monitoring. This, along with the side effects of clozapine, may interfere with treatment adherence. See Tables E2 and E3 in Appendix E for further details about the treatment conditions in these and the other studies assessing psychopharmacological therapies.

Another study addressing KQ1 compared risperidone with other antipsychotics.71 Risperidone has effects similar to clozapine with less serious side effects, but unlike clozapine it is not approved for treatment-resistant schizophrenia.

The final study compared high-dose chlorpromazine (more than 1,400 mg) with standard dose (less than 1,000 mg).70

In all four studies, patients had received a diagnosis of a psychotic disorder (schizophrenia or schizoaffective disorder) and most had a history of violence or aggression. The average age of the patients ranged from 34 to 40 years. In one study, the authors reported that the majority of patients had a co-occurring substance use/dependence disorder.69 See Tables E4 and E5 in Appendix E for more information about the patients enrolled in the studies.

#### Findings

See Table 9 below for a summary of our findings.

Table 9 Strength-of-evidence grade for studies assessing pharmacologic therapies for Key Question 1

Comparison | Outcome | N Studies (N Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect Favored | SOE Grade
Clozapine vs. other antipsychotics | Psychiatric symptoms | 2 (171) | Medium | Consistent | Direct | Imprecise | Antipsychotics other than clozapine | Low
Clozapine vs. other antipsychotics | Independent functioning | 1 (98) | Medium | Unknown (1 study) | Direct | Precise | Clozapine | Insufficient
Risperidone vs. other antipsychotics | Psychiatric symptoms | 1 (20) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
Risperidone vs. other antipsychotics | Institutional infractions | 1 (20) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
High-dose chlorpromazine vs. standard dose | Psychiatric symptoms | 1 (64) | Medium | Unknown (1 study) | Direct | Precise for BPRS, subscales of NOSIE, the general and peak SDAS, and adverse events | Standard dose | Insufficient

BPRS = Brief Psychiatric Rating Scale; NOSIE = Nurses’ Observational Scale for Inpatient Evaluation; N = number; SDAS = Social Dysfunction and Aggression Scale; SOE = strength of evidence

Of the two studies that compared clozapine with other antipsychotics, Balbuena and colleagues (98 patients) measured change in psychiatric symptoms using the BPRS and Martin and colleagues (73 patients) used the Clinician Global Impression of Severity.68,69 Our analysis of the BPRS scores in the Balbuena and colleagues study indicated that psychiatric symptoms decreased for both groups from baseline to 6-month followup, but a statistically significant difference between groups did not exist at followup. In their repeated measures analysis using time and drug group as predictor variables, the authors of the study demonstrated a significantly greater decrease in BPRS scores (indicating a greater decrease in symptoms) for the nonclozapine group. Although no analysis could be completed because of missing data, the authors suggested that time on medication and adherence to treatment may have had an impact on the BPRS scores of the clozapine group.68 See Table F1 in Appendix F for more detail.

In the Martin and colleagues study, no statistically significant difference was observed between patients experiencing very much or much improvement on clozapine compared with the number of patients on other antipsychotics experiencing a similar improvement. Martin suggested that high rates of co-occurring substance misuse and medical and behavioral problems may have had an impact among patients in the clozapine group.69

We gave a low strength of evidence grade to this evidence base because, although there was no statistically significant difference between study arms in either clozapine trial, both studies tended to favor antipsychotics other than clozapine over clozapine for improving psychiatric symptoms.

Besides the above outcomes, Balbuena and colleagues reported on the number of institutional infractions.68 At 12-month followup, count data indicated that 68 percent (32/47) of the patients treated with clozapine remained offense free, compared with 52 percent (14/27) of the patients not treated with clozapine. The difference between groups in number of offenses was not statistically significant (likely due to sample sizes at followup). Balbuena and colleagues also reported a measure of independent functioning, an increase in pay. A significantly greater percentage of patients, about 60 percent, in the clozapine treatment arm received a pay increase versus 30 percent receiving a pay increase in the other antipsychotic medication group.68

Martin and colleagues reported on adverse events for the clozapine group only.69 Overall, 10 percent (5/47) of patients treated with clozapine experienced a serious adverse event. Four percent (2/47) developed neutropenia and 6 percent (3/47) experienced seizures. Further, the authors reported that 15 patients discontinued clozapine at some point during the study for the following reasons: patient refusal, neutropenia, or sedation (2/15 or 13 percent for each); hyperglycemia, hypersalivation, ineffectiveness, seizures, or weight gain (1/15 or 7 percent each).69 See Table F9 in Appendix F for more detail.

Results of the study by Beck and colleagues (20 patients), which compared risperidone with other antipsychotics, did not find any significant difference in levels of adaptive and maladaptive behaviors (as measured by the Time Sample Behavioral Checklist) between patients on risperidone and patients on other antipsychotics at 6-month followup.71 They also failed to find a difference between groups for the parameter of change in the number of aggressive incidents from baseline to followup. The authors reported that patients on risperidone did not display any change in number of aggressive acts from the time they were placed on the medication to followup. One particularly limiting factor in this study was that there was no washout period between the time patients were taken off other antipsychotic medications and put on risperidone. See Table F1 in Appendix F for more detail.

Finally, the overall findings of the study by Tavernor and colleagues, which compared high-dose chlorpromazine with standard dose in a maximum security hospital, indicated that patients receiving the high dose experienced significantly more psychiatric symptoms and adverse events than did patients on the standard dose.70 The patients receiving the high dose demonstrated a higher overall score on the BPRS and on four subscales of the Nurses’ Observational Scale for Inpatient Evaluation (NOSIE).

Specific results for the Tavernor and colleagues study are as follows: for BPRS (standardized mean difference [SMD] 0.744; 95% confidence interval [CI], 0.171 to 1.317; p=0.011); NOSIE subscale social interest (SMD 0.631; 95% CI, 0.129 to 1.133; p=0.014), psychotic depression (SMD 0.750; 95% CI, 0.243 to 1.257; p=0.004), manifest psychosis (SMD 0.883; 95% CI, 0.370 to 1.397; p=0.001), and irritability (SMD 0.587; 95% CI, 0.087 to 1.088; p=0.021).70

Patients in the high-dose group demonstrated higher levels of general and peak aggression than the standard dose group as measured by the Social Dysfunction and Aggression Scale (general SMD 0.532; 95% CI, 0.034 to 1.031; p=0.036; and peak SMD 0.631; 95% CI, 0.125 to 1.137; p=0.014).

The authors also reported that the high-dose group experienced significantly more autonomic and neurological side effects than did the standard dose group (mean score for high-dose group was 6.96, mean for standard dose was 4.84, p=0.048).70 See Tables F1 and F9 in Appendix F for additional information.

#### Applicability

In all of the pharmacologic therapy studies, the patients had a psychotic disorder and most had a history of violence and aggression. The findings of these studies are applicable only to this subset of inmates. Further, these studies took place in forensic hospitals or specialized units in which patients may have been more carefully observed for adverse events than would occur in a nonspecialized jail or prison setting. This is an important point because clozapine and high-dose chlorpromazine are associated with serious adverse events and patients on these medications need to undergo periodic blood tests and be closely monitored. Such attention may not be available in some jails or prisons.

### Psychological Therapies

#### Description of Studies

Three studies that addressed KQ1 evaluated the efficacy of psychological therapies used to treat incarcerated individuals with SMI. Two studies, Rees-Jones and colleagues and Cullen and colleagues, evaluated the use of a cognitive skills program called Reasoning and Rehabilitation (R&R) to treat men incarcerated in secure forensic units located across the United Kingdom.66,67 Both were multisite studies.

In the Rees-Jones trial, 121 males with a diagnosis of schizophrenia or schizoaffective or bipolar disorder were nonrandomly assigned to receive R&R (n=67) or treatment as usual (n=54).66 More than half of these offenders had a history of violence. In the Cullen and colleagues study, 72 men with a primary diagnosis of psychotic disorder and a history of violence were randomly assigned to receive R&R (n=36) or treatment as usual (n=36).67 The majority of the patients in this study had a diagnosis of schizophrenia that was based on Diagnostic and Statistical Manual of Mental Disorders, fourth edition, (DSM-IV) or International Statistical Classification of Diseases and Related Health Problems, 10th Revision (ICD-10) criteria.

Cullen and colleagues did not report whether the patients had a history of substance abuse but did indicate that overall, 44 percent (37 patients) of patients had a co-occurring diagnosis of antisocial personality disorder.67 Neither rates of substance use nor co-occurring personality disorder were reported by Rees-Jones.

The average age of the men enrolled in both studies was 35 years. Cullen and colleagues reported that the median number of previous convictions was five for the R&R group and six for the treatment-as-usual group. The participants in Rees-Jones had between seven and eight earlier convictions, on average.66 For more information about the patients enrolled in this study see Table E4 and E5 in Appendix E.

The R&R cognitive skills program was developed on the premise that many offenders, with or without mental illness, “have failed to develop core social cognitive skills and are therefore nonreflective, impulsive, egocentric, concrete in their thinking, and tend to externalize blame for their actions.”67 The program targets cognitive deficits and maladaptive thinking styles and encourages offenders to develop prosocial skills and behaviors.

In Cullen and colleagues study, the R&R program consisted of 36 sessions, 2 hours each, covering the following eight modules: problem solving, assertiveness skills, social skills, negotiation skills, creative thinking, emotion management, values reasoning, and critical reasoning.67 Groups of five to eight patients received the program, with group sessions held twice or three times weekly, led by staff who received intensive training from the program developers.

Patients in the treatment-as-usual group in the Cullen and colleagues study were free to receive any interventions considered to be part of their usual treatment with the exception of R&R.67 In the Rees-Jones and colleagues study, investigators modified the program for a mentally disordered offender population.66 It consisted of 16 sessions, with individual mentoring between group sessions. See Table E2 of Appendix E for more information about the treatments provided in this study.

Patients in the Wilson study were randomly assigned to receive either group cognitive treatment (n=5) or individual supportive therapy (n=5).72 The patients in this study were incarcerated in a large, maximum-security prison. They had all received a diagnosis of major depression by the referring physician or therapist. The average age of patients was 33 years, and the average length of current incarceration was 28 years. The author did not report whether patients had a history of substance abuse or other co-occurring disorders. See Tables E4 and E5 of Appendix E for more information about the patients in this study.

Therapy in the Wilson cognitive group was based on the assumptions and techniques developed by Beck and colleagues.72 The group sessions were problem-oriented and focused on specific techniques, such as developing activity schedules and recording dysfunctional thinking, as well as on group processes, such as modeling and attention to group interactions. Patients were encouraged to identify, challenge, and modify negative thoughts. Patients were offered 14 sessions of 90 minutes each and were given homework assignments to improve mood and teach adaptive skills. The author of the study delivered the therapy.

The individual supportive therapy was designed to be a brief form of treatment in which patients were encouraged to discuss their moods, current functioning, and personal concerns.72 The treatment avoided using specific cognitive or behavioral techniques and, instead, encouraged patients to deal with problematic issues through reflection. Patients in this group received brief, ongoing, individual supportive sessions lasting 5–10 minutes by the author of the study or the cellblock counselor as part of the standard prison routine. See Table E2 of Appendix E for more details about the therapies provided in the Wilson study.

#### Findings

All included data for these studies appear in Tables F1 through F9 in Appendix F. A summary of findings appears below in Table 10.

Table 10 Strength-of-evidence grade for studies assessing psychological therapies for Key Question 1

Comparison | Outcome | N Studies (N Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect Favored | SOE Grade
Cognitive problem solving group (R&R) vs. treatment as usual | Psychiatric symptoms | 2 (205) | Medium | Unknown (different measures used) | Direct | Precise for the impulsiveness/carelessness and avoidant subscales of the SPSI and MVQ | Cognitive problem solving group | Insufficient
Cognitive group therapy vs. individual supportive therapy | Psychiatric symptoms | 1 (10) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient

MVQ = Maudsley Violence Questionnaire; N = number; R&R = Reasoning and Rehabilitation; SOE = strength of evidence; SPSI = Social Problem Solving Inventory

All three of the studies that evaluated psychological therapies reported on change in psychiatric or behavioral symptoms. The primary outcome in the Cullen and colleagues study was change in social problem solving as measured by the Social Problem Solving Inventory (SPSI).67 The SPSI is a 25-item questionnaire that consists of two subscales that measure problem-solving orientation (positive orientation and negative orientation) and three that measure problem-solving style (rational problem solving, impulsivity/carelessness, and avoidant). Higher scores in the areas of total problem-solving skills, positive problem orientation, and rational problem solving indicate more adaptive functioning. Higher scores for negative problem orientation, impulsivity/carelessness, and avoidant problem solving indicate more maladaptive behaviors.

Rees-Jones and colleagues reported Maudsley Violence Questionnaire (MVQ) total score and Locus of Control (LoC) Scale.66 The MVQ is a 56-item true/false questionnaire assessing machismo and acceptance of violence. Higher scores indicate more violent tendencies. The LoC Scale is a 40-item yes/no questionnaire that measures whether subjects believe events are internally or externally controlled. Higher scores are judged to be worse.66

Cullen and colleagues reported that, at posttreatment, the R&R group demonstrated significant improvement compared with improvement in the treatment-as-usual group on the impulsive/carelessness and avoidant problem-solving style subscales of the SPSI. Results showed the following: for impulsive/carelessness, SMD 0.612; 95% CI, 0.140 to 1.085; p=0.011; and avoidant, SMD 0.557; 95% CI, 0.086 to 1.028; p=0.02. The R&R group continued to demonstrate significant improvement on these subscales at 12-month followup (impulsivity/carelessness, SMD 0.524; 95% CI, 0.054 to 0.994; p=0.029; and avoidant, SMD 0.834; 95% CI, 0.352 to 1.315; p=0.001).67

Our calculation of effect size estimates did not indicate any significant difference between Cullen and colleagues groups on the SPSI total score or most of the subscales. However, in their post-hoc analysis of treatment completers, the authors found that the R&R group improved significantly compared with improvement in the treatment-as-usual group on the total score of the SPSI (p=0.04 at posttreatment and p=0.01 at 12-month followup).

Results of the Rees-Jones and colleagues study indicate that the R&R group significantly reduced their violent tendencies by the 3-month followup compared with violent tendencies measured in the treatment-as-usual group.66 The authors noted no significant group difference for the LoC measure.

Wilson measured change in psychiatric symptoms using multiple instruments (see Table 8 for a list of the instruments used in this study).72 At posttreatment and at 9-month followup, no statistically significant differences were observed between the cognitive therapy group and the individual supportive therapy group on any of the instruments used to measure depression or other psychiatric symptoms.

Because of differences in the interventions, outcomes reported, and diagnostic enrollment criteria, these studies were not combined in the strength-of-evidence grades that follow. The R&R trials were not combined because each study reported different outcome measures, with R&R participants outperforming the treatment-as-usual group on some but not all measures. Additionally, all three of the studies that evaluated psychological therapies for incarcerated individuals with SMI had limitations. The primary limitations in the Cullen and colleagues study were possible selection bias and attrition bias in the R&R group.67 Only half (21 of 42) of the patients randomly assigned to the R&R group completed treatment. A major limitation of the Rees-Jones and colleagues study was that study assignments were not made independently from physician or patient preference, possibly resulting in selection bias.66

In a separate publication, Cullen and colleagues examined treatment dropout among the 42 patients who were assigned to the R&R group.77 The goal of the analysis in this study was to determine which patient characteristics (demographic, behavioral, and clinical) predicted dropout. The authors of the study reported that “program noncompletion was significantly predicted in univariate analysis by current and future violence risk, antisocial traits, and recent violence.” Multivariate analysis indicated that psychopathy, antisocial personality disorder, and recent violence were the strongest predictors of failure to complete treatment.

The main limitation of the Wilson study was the small sample.72 Only 10 inmates agreed to participate in this study. As indicated by the author, such a small sample size limits the ability to uncover any meaningful differences between the two treatment groups.

#### Applicability

We further evaluated the studies that assessed psychological therapies for incarcerated individuals with SMI to identify factors that could potentially affect the applicability of the evidence. The patients enrolled in the three studies represent the heterogeneity of incarcerated individuals with SMI. In two studies, the patients had a diagnosis of schizophrenia or bipolar disorder and all or most had a history of violence. In the other study, the patients had a diagnosis of depression. The inclusion/exclusion criteria of the studies include items that may limit the generalizability of the findings of the studies. For instance, the Cullen and colleagues study excluded patients with cognitive deficits67 and the Wilson study excluded patients who were taking medication or involved in other treatment for their depression.72 All three studies enrolled only male inmates. The findings of the studies may not be applicable to female inmates.

In general, providing incarcerated individuals with psychological therapy can be challenging. Inmates in the Wilson study were incarcerated in a maximum security prison in which the author indicates they were in “lock-down” for 23 hours a day.72 Further, as evidenced by the high attrition rate of patients assigned to the R&R group in the Cullen and colleagues study, certain treatments may not be easily adaptable to inmates with SMI. The R&R program was originally developed for incarcerated individuals without mental illness. The investigators adapted it for use in offenders with mental disorders on the basis that they demonstrate patterns of criminal thinking and behavior similar to offenders without mental disorders. However, as Cullen and colleagues point out, the program may be too demanding or may not meet the needs of offenders with SMI, particularly those who have a history of violence and antisocial behavior.77 Rees-Jones and colleagues attempted to overcome this limitation by decreasing the number of sessions required by inmates and adding an individual mentoring component.66 These adaptations may have been beneficial because their dropout rate was relatively low (22 percent).

### Dual-Disorder Treatments

#### Description of Studies

Two studies assessed the efficacy of MTCs for offenders with co-occurring mental illness and substance use disorders.61,64 Both studies were RCTs that compared the outcomes of inmates randomly assigned to MTC with outcomes in subjects randomly assigned to more standard in-prison mental health and substance abuse services. Both studies took place in correctional facilities located in urban areas in Colorado.

Both studies were reported in multiple publications. One study, by J. Sacks and colleagues, reported preliminary, 6-month, postprison outcome data64 in one publication64 and 12-month postprison outcome data in a second.65 Because the investigators were still recruiting patients at the time of the first publication, the second publication included an additional 154 patients. We relied mainly on the first publication in writing our review because the quality of data reporting was superior. The second study of MTC reported on different outcomes for the same patient population in three separate publications—one each reporting on criminal justice outcomes,61 mental health outcomes,63 and substance use outcomes.62

In the study by J. Sacks and colleagues, all participants were female, with an average age of 35 years (n=468).64,65 The average length of incarceration in this study was 1.1 years with most inmates being incarcerated for a drug-related crime.

Based on DSM-IV diagnostic criteria, 69 percent of the participants in the J. Sacks and colleagues study would have received a lifetime diagnosis of severe mental disorder (mania or hypomania, bipolar disorder, or major depression) and 75 percent would have received a lifetime diagnosis of one or more Axis I disorders, with the majority (65 percent) having major depression. The patients had, on average, two Axis I mental disorder diagnoses. The women’s primary substances of choice were crack/cocaine (30 percent), alcohol (23 percent), methamphetamine (19 percent), marijuana (18 percent), and opiates (7 percent).

In the other study, by the S. Sacks and colleagues, all participants were male, with an average age of 35 years (n=139).61 The average length of incarceration in this study was 4.5 years with most inmates having committed a drug-related crime in the year before incarceration.

Based on DSM-IV diagnostic criteria, 90 percent of patients in the J. Sacks and colleagues study had a substance use disorder, 78 percent had an Axis I mental disorder diagnosis, and 37 percent had a co-occurring personality disorder. The primary drugs of choice were marijuana (34.5 percent), alcohol (32.0 percent), and crack/cocaine (21.0 percent). See Tables E4 and E5 in Appendix E for more information about the patients enrolled in these studies.

In both studies, the authors modified existing models of therapeutic community programs for substance users to accommodate offenders with co-occurring mental and substance use disorders. The MTC programs in the studies that addressed KQ1 used “a cognitive behavioral curriculum within the foundation of therapeutic community principles to change attitudes and lifestyles in three critical areas: substance abuse, mental illness, and criminal thinking.”61 The principles of traditional therapeutic communities involve developing and fostering a community of both offenders and staff, in which members are encouraged to help themselves and others while using the community as part of the treatment. Within the therapeutic community population, inmates are provided with opportunities for leadership, for exercising authority in a positive manner, and for becoming positive role models. Program participants are housed together in prison, separate from the general inmate population.

The MTC programs in each study included psychoeducational classes, cognitive behavior protocols, medication, and other therapeutic interventions. See Tables E2 and E3 in Appendix E for more information about the delivery and duration of the interventions provided within the MTC in each study.

In the study by J. Sacks and colleagues, investigators further adapted the MTC program to meet the needs of female offenders with co-occurring disorders.64,65 In this study, inmates were provided with gender-specific interventions that addressed trauma and abuse, parenting, and relationships.

In the study by S. Sacks and colleagues, participants in the MTC program were eligible to enter the MTC residential aftercare program upon release from prison.61 Entry into the aftercare program was voluntary and based on the inmate’s preference. However, the authors of the study indicated that entry was never strictly voluntary, because agreeing to enter often facilitated parole approval.

The control condition in the study by S. Sacks and colleagues involved a mental health program that consisted of intensified psychiatric services that included medication, weekly individual therapy and counseling, and specialized groups.61 The substance abuse services consisted of a 72-hour cognitive behavior core curriculum that focused on substance abuse education and relapse prevention. Inmates enrolled in the mental health program were offered aftercare services upon release from prison. The mental health aftercare program included a variety mental health services provided by a community-based agency in an outpatient setting.

The control condition in the study by J. Sacks and colleagues was similar.64,65 In this study, women in the intensive outpatient program (IOP) received a range of services that included mental assessment, psychiatric evaluation, medication, and counseling. The IOP substance abuse treatment curriculum consisted of a 90-hour course that used a cognitive behavior format to address underlying issues of substance abuse and criminal behavior. The authors of this study reported that a majority of participants in the MTC or IOP programs received some services upon release but did not provide detail about these services. See Tables E2 and E3 in Appendix E for more information about the delivery and duration of the control interventions in each study.

#### Findings

All included data for these studies appear in Tables F1 through F9 in Appendix F. A summary of findings appears below in Table 11.

Table 11 Strength-of-evidence grade for studies assessing dual disorder therapies for Key Question 1

Comparison | Outcome | N Studies (N Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect Favored | SOE Grade
MTC vs. IOP J. Sacks et al.64,65 | Psychiatric symptoms | 1 (468) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
MTC vs. MH Sullivan et al. (2007b)63 | Psychiatric symptoms | 1 (139) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
MTC vs. IOP J. Sacks et al.64,65 | Substance use or abuse | 1 (468) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
MTC vs. MH Sullivan et al. (2007a)62 | Substance use or abuse | 1 (139) | Medium | Unknown (1 study) | Direct | Precise for all measures of substance use/abuse including reduction in use, severity of use, and time to relapse | MTC | Insufficient
MTC vs. IOP J. Sacks et al.64,65 | Criminal justice outcomes | 1 (468) | Medium | Unknown (1 study) | Direct | Precise for reduction in arrests for crimes other than parole violations at the 6-month followup | MTC | Insufficient
MTC vs. MH S. Sacks et al.61 | Criminal justice outcomes | 1 (139) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient

IOP = intensive outpatient program; MH = usual mental health services; MTC = modified therapeutic community; N = number; SOE = strength of evidence

Because of variations in the interventions assessed and study participant sex differences, these two trials were not combined in the qualitative analysis that follows. Psychiatric symptoms in the study by J. Sacks and colleagues were measured using the BDI, the BSI, and the Posttraumatic Symptom Scale (PSS).64,65 Scores for all three measures of psychiatric symptoms demonstrated statistically significant improvement for both the MTC and IOP group from pretreatment to 6-month followup. Our calculations of individual effect size estimates did not find a statistically significant difference between groups on any of these measures. However, the authors report they found statistically significant differences on the BDI and PSS favoring the therapeutic community group at the 6 month followup.64,65 According to the authors, one-third of the women in each group remained on psychotropic medication upon release from prison. Thus, differences in psychological symptoms cannot be attributed to differences between the groups in terms of medication adherence. The authors also report that participants in the IOP study arm continued to improve through the 12-month followup, causing the two groups’ scores on these measures of mental health symptomology to converge.

Psychiatric outcomes of participants in the S. Sacks and colleagues study were reported in a separate publication by Sullivan et al (2007b).63 Symptoms in this study were measured using the BDI, BSI, and Manifest Anxiety Scale. The authors did not report data from the measures of psychiatric symptoms in a manner that allowed us to calculate individual study effect size estimates. However, according to the authors’ reported results, no significant differences were detected between the MTC and mental health program groups from baseline to 12-month followup on any measures of symptom change or on measures of medication use or treatment involvement. The authors suggest that the following limitations may have affected the ability of the study to demonstrate positive mental health effects: small sample size, the use of psychotropic medications by both groups before entry into the study, and the high level of trauma experienced by both groups.

J. Sacks and colleagues assessed substance use/abuse and other related problems through self-reported information on the subjects’ historic and current frequency of use of alcohol, illegal substances, misuse of prescribed medication, perceived problems related to substance use, and historic and current substance-abuse treatment.64,65 The results of both our analysis of individual effect size estimates and the authors’ analysis indicated that both the MTC and IOP groups showed significant reductions on all measures of substance abuse (alcohol use, substance use, frequency of alcohol use, and highest frequency of drug use) from baseline to 6-month followup, with no significant differences between the groups on any of the measures. The authors also reported that the magnitude of the reported improvements appeared to be similar for each group. According to the authors, a number of factors might explain the lack of differences between groups, including the strength of the comparison treatment, the dosage, and the receipt of substance treatment after prison release. This pattern continued at the 12-month postprison followup.

Substance use outcomes of participants in the S. Sacks and colleagues study were reported in a separate publication by Sullivan and colleagues (2007a).62 Self-reported data were collected on any substance use, use of alcohol, use of illegal substances, severity of use, and time to relapse. Using data from the 12-month followup, our analysis indicated a statistically significant reduction favoring the MTC group over the mental health program group in any substance use (SMD 0.344; 95% CI, 0.171 to 0.690; p=0.003) and in use of illegal substances (SMD 0.436; 95% CI, 0.213 to 0.894; p=0.023). This is consistent with the authors’ findings. The authors also found greater reduction in alcohol use for the MTC group compared with alcohol use in the mental health–program group. Further, according to the authors’ findings, the MTC group had greater reductions in the severity of substance use and frequency of alcohol used to intoxication. MTC treatment also significantly reduced the likelihood of relapse (3.7 months vs. 2.6 months, p≤0.05).

Finally, J. Sacks and colleagues considered the following measures of criminal behavior: self-reported information about historic and current criminal justice involvement (including any arrest, arrest for crimes other than parole violation, any criminal acts, drug-related crimes, and sex crimes, reincarceration, and time to reincarceration) and frequency of illegal activities.64,65 Both the authors’ and our analysis indicated that women in the MTC group showed significantly greater reduction in arrests for crimes other than parole violations (SMD 0.377; 95% CI, 0.195 to 0.729; p=0.004) than women in the IOP group at the 6-month followup. However, by the 12-month followup, the two groups were similar in arrest rates. No statistically significant between-group differences were observed for any other criminal justice outcome.

The criminal justice outcomes reported in the study by S. Sacks and colleagues included reincarceration, involvement in criminal activity, offenses related to alcohol or substances, and nonalcohol or nonsubstance offenses.61 Our findings and those of the authors indicated no statistically significant differences in any of the criminal justice outcomes between the MTC-only group and the standard mental health program group. Statistically significant differences were observed only between men who received both in-prison MTC and MTC aftercare and those who received standard mental health and substance use services. Because the men in the MTC plus aftercare were self-selected and not randomly assigned, we did not consider the differences between this group and the standard mental health group when we assessed the strength of evidence for this study. Table 11 shows strength of evidence for the studies assessing dual disorder therapies for KQ1.

#### Applicability

The findings of the studies assessed in this section demonstrate that therapeutic communities can be adapted within a prison setting to treat individuals with co-occurring mental health and substance use disorders. Also, therapeutic communities within the prison setting can be further adapted to meet the gender-specific needs of male and female offenders.

Of the two studies that evaluated MTCs, one included prisons housing only men61 and the other was set in a facility for women.64,65 The findings of each study indicated differences in the outcomes of women versus men. Women who received MTC treatment demonstrated improvement on some psychological measures according to the authors’ calculations and on criminal justice outcomes. However, they failed to demonstrate greater improvement than the standard-of-care group on all measures of substance use/abuse. Men who received MTC showed significant improvement on all substance-abuse measures compared with improvement of men in the standard of care group, but failed to demonstrate improvement on any measure of psychiatric symptom change. Further, only the men who went on to receive MTC aftercare demonstrated statistically significant reductions on criminal justice outcomes compared with those outcomes in subjects who received more standard prison services for mental health and substance use disorders.

Of course, it is difficult to determine whether these differences are due to gender-specific responses to treatment or to study-specific factors such as sample size, differences in the characteristics of the MTC programs, strength of the comparison treatment, or other differences in participant characteristics.

## KQ2 Incarceration Setting to Community Transitional Interventions

KQ2. What is the comparative effectiveness of incarceration-to-community transitional interventions for adults with SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a co-occurring alcohol/substance abuse diagnosis? Is there a difference in the comparative effectiveness of interventions based on the setting (jail to community, prison to community, forensic hospital to community) in which the interventions are provided?

### Key Points

- Evidence of low strength demonstrated an increase in service use following release from incarceration with treatment that included discharge planning and assistance applying for health benefits. The two trials that incorporated discharge planning with application assistance had other treatment components as well; therefore, it is unclear if the increased service use was entirely a result of application assistance in both of these trials or another component of treatment.
- Evidence of low strength indicated that psychiatric hospitalizations were reduced and service use, both during incarceration and upon release, was increased among clients who received integrated dual diagnosis treatment (IDDT) compared with psychiatric hospitalization and service use among clients who received other, nondual-diagnoses treatments.
- Evidence for the impact of specialist versus mental health generalist care on psychiatric symptoms, psychiatric hospitalization, substance abuse, quality of life, and completed suicide was rated as insufficient because only one trial reported these outcomes for these comparisons.
- Evidence was also insufficient for assessing the effect of interpersonal therapy (IPT) versus psychoeducation for psychiatric symptoms and substance abuse because only one trial assessed this intervention comparison.

### Description of Included Studies

For KQ2, we reviewed studies that evaluated interventions that were provided during incarceration within a jail, prison, or forensic hospital and continued upon release into the community. To be eligible, studies must have covered one or more of the interventions of interest in the settings addressed in KQ2 listed in the Introduction under “Providing Mental Health Services to Offenders With SMI Transitioning From Incarceration to the Community.” The studies must have compared one of the identified interventions with another intervention or with standard care or treatment as usual. Studies that compared an intervention with a waitlist control or with a no-treatment group were not considered for this question. We also considered whether there was a difference in the comparative effectiveness of interventions based on the setting (i.e., jail to community, prison to community, forensic hospital to community) in which the interventions were provided.

Seven comparative trials (3 RCTs and 4 nonrandomized) enrolling 2,559 subjects addressed KQ2. The interventions assessed were quite varied but may be divided into four categories: discharge planning with benefit-application assistance, dual diagnoses treatment; specialist-versus generalist-provided treatment, and IPT versus psychoeducation. Two studies assessed treatments that included discharge planning with benefit-application assistance, three comprehensive interventions treated inmates who had dual diagnoses, two studies compared treatment provided by a forensic specialist with treatment provided by a mental health generalist, and one trial compared IPT with psychoeducation. Because the Mentally Ill Offender Community Transition Program (MIOCTP) incorporates both discharge planning with benefit-application assistance and dual diagnosis treatment, we included this study in the analysis of both of those treatment categories.78 See Table 12 for more details.

Table 12 Characteristics of included studies for Key Question 2

Reference | Number of Patients | Study Design | Treatment | Comparator | Setting
Johnson and Zlotnick, 2012^35^ | 38 | Randomized controlled trial | IPT | Psychoeducation | Prison to community
Wenzlow et al., 2011^79^ | 686 | Nonrandomized comparative trial | Discharge planning with benefit-application assistance | Treatment as usual | Prison to community
Theurer and Lovell, 2008^78^ | 128 | Nonrandomized comparative trial | MIOCTP (this treatment includes discharge planning with benefit-application assistance and co-occurring disorder treatment) | Residential MH treatment program in prison; treatment as usual upon release | Prison to community
Coid et al., 2007^80^ | 1,061 | Nonrandomized comparative trial | Forensic specialist psychiatric services | General adult psychiatric services | Forensic unit of a psychiatric hospital to community
Chandler and Spicer, 2006^81^ | 182 | Randomized controlled trial | Jail: intensive assessment, 1-on-1 counseling, and crisis intervention Community: high-fidelity IDDT | Jail: intensive assessment, 1-on-1 counseling, and crisis intervention Community: treatment as usual | Jail to community
Van Stelle and Moberg, 2004^82^ | 278 | Nonrandomized comparative trial | MICA in prison and upon release into community | Treatment as usual | Prison to community
Solomon and Draine, 1995^83^ | 176 | Randomized controlled trial | Jail: mental health services Community: ACT | Jail: forensic mental health services Community: intensive case management Jail: mental health service Community: treatment as usual | Jail to community

ACT = assertive community treatment; IDDT = integrated dual diagnosis treatment; IPT = interpersonal therapy; MH = mental health; MICA = mentally ill chemical abuser (treatment); MIOCTP = Mentally Ill Offender Community Transition Program

Six of the seven trials were conducted in the United States35,78,79,81–83 and the seventh was conducted in the United Kingdom.80 Three trials were conducted in urban areas within the United States,78,81,83 three did not describe the location,35,79,82 and the seventh trial, conducted in the United Kingdom, covered inmates in both urban and rural areas.80 In all seven trials, treatment was initiated during incarceration and was continued upon release into the community. In four of the seven trials, the incarceration setting was prison,35,78,79,82 in two it was jail,81,83 and in the final trial it was a medium-secure psychiatric hospital.80 See Table E6 in Appendix E for more detail.

The inclusion criteria for patient enrollment appear in Table 13.

Table 13 Participant inclusion and exclusion criteria for Key Question 2

Study | Participant Inclusion Criteria (as described in article) | Participant Exclusion Criteria (as described in article)
Johnson and Zlotnick, 2012^35^ | Primary (nonsubstance induced) major depressive disorder diagnosis determined by the Structured Clinical Interview for DSM-IV Axis I disorders after at least 4 weeks of abstinence and prison substance abuse treatment. Patients also needed a minimum score of 18 on the Hamilton Depression Scale, met criteria for a substance use disorder 1 month before incarceration, and were 10–24 weeks away from prison release. | Patients with bipolar disorder or psychotic disorder
Wenzlow et al., 2011^79^ | Adults aged 18 years or older in whom major depression, bipolar disorder, or psychotic illness had been diagnosed who were identified as requiring intensive treatment and released from 1 of 3 correctional facilities in Oklahoma between July 2007 and March 2008 | Adults who required 24-hour monitoring
Theurer and Lovell, 2008^78^ | MIOCTP: major mental illness that influenced previous criminal activity; judged as less likely to reoffend if provided with ongoing MH treatment; unlikely to obtain housing/treatment from another source; a minimum of 3 months remaining on sentence; willing to participate MH treatment: Participants in this group were matched on 8 pre-identified factors found to be important predictors of recidivism; released from prison between 1996 and 2000 | Level 3 sex offender
Coid et al., 2007^80^ | Patients admitted to a medium-secure forensic hospital; psychiatry services provided by 7/14 prereorganization Regional Health Authorities in England and Wales 1989–1993 | Not reported
Chandler and Spicer, 2006^81^ | Jail inmates with current SMI and current substance abuse disorder; not sentenced to prison, not on parole, and not a resident of another county; not currently enrolled in another Alameda County treatment program; Global Assessment of Functioning score of ≤50; fluent in English or Spanish; and at least 2 jail episodes in the 2 years before the index admission or spent 90 days in jail in the past 2 years | Not reported
Van Stelle and Moberg, 2004^82^ | Male prisoners who had committed a felony and had severe and persistent mental illness and substance abuse diagnoses. The control group was made up of similar individuals who were being released in less than 18 months and so were not entered into the therapeutic community. | Not reported
Solomon and Draine, 1995^83^ | Inmates of a large urban city jail expected to be released in 4–6 weeks with a major mental illness (schizophrenia, affective, or personality disorder) according to the DSM-III-R; Global Assessment of Functioning score ≤40 if older than age 35 years or ≤60 if 35 years of age or younger; recent extended MH treatment including community hospitalization, outpatient treatment, or State hospitalization; and did not have housing upon release | Refused to consent

DSM-III-R = Diagnostic and Statistical Manual of Mental Disorders, third edition, revised; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, fourth edition; MH = mental health; MIOCTP = Mentally Ill Offender Community Transition Program; SMI = serious mental illness

Table 14 lists the outcomes reported for each of the studies that addressed KQ2. In both the Wenzlow and colleagues79 and Theurer and Lovell78 studies, only subjects with a major mental disorder who required ongoing assistance were enrolled. Wenzlow and colleagues excluded individuals requiring 24-hour monitoring and Theurer and Lovell excluded Level III sex offenders.

Table 14 Included studies and outcomes for Key Question 2

Reference | Completed Suicide | Quality of Life | Independent Functioning | Psychiatric Symptoms | Substance or Alcohol Use | Hospitalization for SMI | Time to Relapse | Infractions of Prison Code | Recidivism | Reincarceration | Mental Health Service Use^*^ | Adherence to Treatment^*^
Johnson and Zlotnick, 2012^35^ | | | | ✓ | ✓
Wenzlow et al., 2011^79^ | | | | | | | | | | | ✓
Theurer and Lovell, 2008^78^ | | | | | | | | | ✓ | | ✓
Coid et al., 2007^80^ | ✓ | | | | | ✓ | | | ✓
Chandler and Spicer, 2006^81^ | | | | ✓ | | ✓ | | | ✓ | | ✓
Van Stelle and Moberg, 2004^82^ | | | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Solomon and Draine, 1995^83^ | ✓ | ✓ | | ✓ | ✓ | | ✓ | | | ✓

* Intermediate outcomes.

SMI = serious mental illness

All of the studies reported at least one mental health outcome (including mental health service use), and five out of seven reported at least one criminal justice outcome as well.78,80–83 One trial each reported function82 and quality of life.83 None of the trials reported treatment-related adverse events.

The studies that reported on increases in psychiatric symptoms and rehospitalization used administrative records; the BPRS, a 1-page, 16–18 item scale measuring self-report and physician-observation of affect and psychotic symptoms; or the Hamilton Rating Scale for Depression (HRSD), a 17-item scale measuring depressive symptoms.35,74 The single study that reported patient function and medication adherence used agent-reported data.82 Substance abuse was reported by three studies;35,82,83 two used urinalysis to determine substance use and the other, the alcohol scale of the Addiction Severity Index. The Addiction Severity Index is a semistructured interview with seven parts, one of which is alcohol use. It covers the past 30 days as well as lifetime use.84 Service use, suicide, infractions, and criminal justice outcomes were measured using administrative data.

Solomon and Draine reported quality of life measured with the Lehman’s Quality of Life Interview.83 This tool is a measure developed for people with severe and persistent mental illness. It is a structured interview that requires administration by a trained interviewer. Quality of life is assessed across eight domains: living situation, daily activities and functioning, family relations, social relations, finances, work and school, legal and safety, and health.85

### Risk-of-Bias Assessment

Our risk-of-bias assessments for the studies that address KQ2 appear in Table D2 of Appendix D. Six trials were categorized as medium risk of bias78–83 for all reported outcomes and the seventh was graded low risk of bias35 for both of its reported outcomes. The most common reasons for the medium risk of bias for these studies were lack of randomization (4 trials),78–80,82 use of subjective outcome measures (e.g., psychiatric symptoms, substance abuse, quality of life), lack of blinding of outcome assessors (either not performed or not reported, all 6 trials), poor treatment fidelity (3 trials),78,79,83 lack of reporting of ancillary treatment or large differences by treatment group (5 trials),78–80,82,83 and high attrition (3 trials).81–83 The single low risk-of-bias trial was randomized, blinded the outcome assessors, reported high treatment fidelity, reported ancillary treatments, and had low attrition.35

### Discharge Planning With Benefit-Application Assistance

#### Description of Studies

In two trials, Wenzlow and colleagues and Theurer and Lovell, the authors described a treatment that included a discharge-planning component in which subjects received assistance with applying for benefits.78,79 In the Wenzlow and colleagues study, discharge-planning managers employed by the State mental health agency to work in correctional facilities helped prison inmates apply for Federal disability benefits and Medicaid benefits 4 and 2 months before their scheduled release date, respectively. In the other three trial arms assessed by Wenzlow and colleagues, inmates did not receive application assistance, just treatment as usual in the community upon release. Subjects in the trial were followed up for 3 months after release.79

In the Theurer and Lovell trial, subjects in the MIOCTP received assistance with the entitlement application process while in prison, besides other services including postrelease case management, individual and group therapy, housing assistance, co-occurring disorders treatment, and increased monitoring by community corrections officers.78 The subjects in the comparison arm of this trial resided in a mental health program while in prison and received treatment as usual upon release. Theurer and Lovell trial subjects were followed up in the community for 2 years.

A minority of subjects in the Wenzlow and colleagues trial received ancillary treatment with a Reentry Intensive Care Coordination Team (RICCT).79 Wenzlow reports that because the focus of RICCT is not on application assistance, receipt of this service did not affect mental health service use after release. Theurer and Lovell did not report that subjects in their study received ancillary treatment.78 In both trials, treatment fidelity was noted to be poor. See Tables E7 and E8 in Appendix E for more information on this and other treatment characteristics.

Subjects in both of these trials tended to be young men, approximately half of whom were Caucasian. More than half of the subjects in the Wenzlow and colleagues trial had basic literacy skills, and between 70 percent and 80 percent had an earlier or current felony conviction.79 The Theurer and Lovell publication did not report the literacy level or rate of felony convictions of its participants.78

Approximately 27 percent of subjects in the Wenzlow and colleagues trial had an earlier or current felony conviction,79 and 37 percent of those in the MIOCTP arm of the Theurer and Lovell study had such a conviction record.78 Twenty-two percent of subjects in Wenzlow and colleagues study were incarcerated for 5 years or more. Theurer and Lovell did not report length of conviction. About 5 percent of the Wenzlow study subjects were enrolled in Medicaid at study entry; Theurer and Lovell did not report this participant characteristic. See Tables E9 and E10 in Appendix E for more detail.

All subjects in the Wenzlow and colleagues trial were described by study authors as having a primary diagnosis of major depression, bipolar disorder, or a psychotic illness, without further detail.79 In the Theurer and Lovell trial, 56 percent of MIOCTP subjects had a psychotic disorder, 20 percent had depression, and 20 percent, bipolar disorder.78 Three percent of subjects had another diagnosis that was not further defined. All participants in the Wenzlow and colleagues trial met C1 mental health service classification, indicating an SMI. Wenzlow and colleagues did not report any other diagnoses of its participants. A mental health risk-assessment specialist diagnosed the mental health conditions in the participants in the Theurer and Lovell trial; 89 percent of its subjects had a co-occurring chemical dependence or abuse diagnosis, and a little more than half had a co-occurring personality disorder. See Tables E9 and E10 in Appendix E for more information.

#### Findings

See Table 15 for a summary of findings.

Table 15 Strength-of-evidence grade for studies assessing discharge planning with benefit-application assistance for Key Question 2

Comparison | Outcome | Number of Studies (Number of Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect | SOE Grade
Discharge planning with benefit-application assistance | MH service use upon release | 2 (814) | Medium | Consistent | Indirect | Imprecise | Discharge planning with benefit-application assistance | Low

MH = mental health; SOE = strength of evidence

Mental health service use upon release from incarceration was reported by both of the studies of discharge planning with application assistance.78,79 Both the Wenzlow and colleagues and Theurer and Lovell trials found discharge planning including application assistance led to more mental health service use than no application assistance. Specifically, Wenzlow and colleagues reported application assistance to be associated with a 16 percent increase in any Medicaid mental health service, a 14 percent increase in outpatient Medicaid mental health services, and a 10 percent increase in Medicaid-covered prescription drug mental health services within 90 days of release from incarceration.79 Theurer and Lovell made comparisons between MIOCTP participants and a larger, unmatched control group, but they also found that those receiving application assistance used more services and received them sooner upon release from incarceration.78 MIOCTP subjects received 92 hours of service within the first 90 days after release compared with just 5.5 hours for control subjects. Likewise, MIOCTP subjects received services sooner upon release (2.3 days vs. 185 days). See Table F20 in Appendix F for further detail.

#### Applicability

In both of the studies of discharge planning with benefit-application assistance, the population was made up of young men with an SMI, about half of whom were Caucasian. About one-third had a prior or current conviction for violent crime. These are the only participant characteristics that were reported by both trials. The findings presented here may be applicable only to this subset of inmates.

It is important to note that 89 percent of subjects in the Theurer and Lovell study also had a co-occurring chemical dependence or abuse diagnosis and a little more than half had a co-occurring personality disorder.78 These characteristics were not reported by Wenzlow and colleagues. See Tables E9 and E10 in Appendix E for more detail.

### Integrated Dual-Disorder Treatments

#### Description of Studies

Three studies describe treatments for individuals with dual diagnoses versus treatment as usual in the community.78,81,82

The Van Stelle and Moberg study described a mentally ill chemical abuser (MICA) therapeutic community, participation in which was started in prison and continued in the community upon release.82 The in-prison program included daily group and individual mental health and substance abuse counseling sessions, sessions to deal with issues that arose in the community living setting, structured social activities, and classes on topics such as anger management and improving one’s physical health. Upon release, prisoners met monthly with specially trained staff members, were closely monitored for medication adherence, and received assistance in obtaining community services. In the other trial arm, subjects received treatment as usual in the community. Followup lasted for 1 year, and investigators did not report treatment fidelity.

In the second trial to assess dual diagnoses treatment, Chandler and Spicer, jail inmates in both trial arms received intensive assessment, medication, discharge planning, counseling, and crisis intervention while in custody.81 Upon release, one group of subjects received high-fidelity IDDT in the community while other subjects received treatment as usual in the community, supplemented by housing assistance and up to 60 days of case management. Subjects were observed for a maximum of 2.5 years, and the authors did not report treatment fidelity.

In the third trial, Theurer and Lovell, subjects in the MIOCTP received assistance with the entitlement-application process while in prison besides other services including postrelease case management, individual and group therapy, housing assistance, co-occurring disorders treatment, and increased monitoring by community corrections officers.78 The subjects in the comparison arm of this trial resided in a mental health program while in prison and received treatment as usual upon release. Subjects were observed in the community for 2 years. The investigators noted that treatment fidelity was poor in this trial.

None of these trials reported that subjects received ancillary treatments. See Tables E7 and E8 in Appendix E for these and other treatment characteristics.

In terms of substance abuse and criminality, participants in the Van Stelle and Moberg and Chandler and Spicer trials must have had a co-occurring substance abuse diagnosis and to have committed either a felony or been arrested two times in the 2 years preceding the index offense or to have spent a minimum of 90 days in jail, respectively, to be enrolled.81,82 The Theurer and Lovell study did not require subjects to have a dual diagnosis, but 89 percent of its participants did. The study enrolled subjects with a major mental illness and a criminal history believed to have been affected by that mental illness and who were judged to be poor candidates for successful community reintegration without ongoing assistance.78

All subjects in the Van Stelle and Moberg study had a current or earlier felony conviction (more than 40 percent for crimes of violence).82 A little more than a third of subjects in the Theurer and Lovell trial had an earlier or current conviction for violent crime.78 Chandler and Spicer81 study subjects had two or more jail episodes within the past 2 years or spent at least 90 days in jail. This suggests more criminality in the Van Stelle and Moberg sample than in the other two trials. MICA (Van Stelle and Moberg study) participants were incarcerated for 7.6 years, on average. Length of incarceration was not reported by the other two studies. None of these trials reported the percentage of clients with Medicaid at study entry. See Table E9 in Appendix E for more information.

Patient characteristics in the two dual-diagnoses treatment trials, Van Stelle and Moberg and Theurer and Lovell, showed that the enrolled subjects were, on average, 36 years of age. A majority of subjects in the third trial, Chandler and Spicer, were between 36 and 50 years of age.81 Van Stelle and Moberg and Theurer and Lovell study participants were more likely to be Caucasian than those enrolled in the Chandler and Spicer trial (43 percent, 51 percent, and 21 percent, respectively), and all three trials enrolled subjects that were predominantly male. The mean Test of Adult Basic Education score in Van Stelle and Moberg subjects was 6.6, indicating a sixth-grade reading level.82 Neither Theurer and Lovell nor Chandler and Spicer reported a measure of basic literacy.

All three dual-diagnoses treatment studies used trained clinical staff members to diagnose SMI in their samples.78,81,82 The clinical staff members in the Chandler and Spicer study81 were aided in their diagnostic assessment by use of the Psychiatric Research Interview for Substance and Mental Disorders (PRISM) tool; clinicians in the Van Stelle and Moberg study82 used a variety of tools to determine the primary diagnosis. Van Stelle and Moberg enrolled 21 percent of subjects with diagnoses that did not meet this report’s definition of SMI: drug-related psychotic disorder (11 percent), other (5 percent), no Axis 1 diagnosis (4 percent), and anxiety or mood disorders (1 percent).

A majority of subjects in the Van Stelle and Moberg and Chandler and Spicer investigations had received a diagnosis of alcohol or substance abuse. Theurer and Lovell reported that 89 percent of subjects had co-occurring chemical dependence or abuse, although that was not a requirement for enrollment.78 None of the subjects in the MICA therapeutic community arm of the Van Stelle and Moberg trial had a co-occurring personality disorder, and the authors did not report the posttraumatic stress disorder rate.82 Eight percent of the sample of the Chandler and Spicer study81 had either co-occurring posttraumatic stress disorder or another anxiety disorder, and half of the subjects in the Theurer and Lovell trial had a co-occurring personality disorder.78 See Table E10 in Appendix E for more detail.

#### Findings

See Table 16 for a complete list of findings.

Table 16 Strength-of-evidence grade for studies assessing interventions for dual disorders for Key Question 2

Comparison | Outcome | Number of Studies (Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect | SOE Grade
Intensive jail treatment followed by high-fidelity IDDT vs. intensive jail treatment followed by treatment as usual | Psychiatric symptoms (crisis visits) | 1 (182) | Medium | Unknown (1 study) | Direct | Precise | High-fidelity IDDT | Insufficient
IDDT vs. treatment as usual in the community | Psychiatric hospitalization (administrative records) | 2 (460) | Medium | Consistent | Direct | Precise | IDDT (MICA and high-fidelity IDDT) | Low
MICA vs. treatment as usual | Function (correctional facility agent reports) | 1 (278) | Medium | Unknown (1 study) | Direct | Imprecise | MICA | Insufficient
MICA vs. treatment as usual | Medication adherence (correctional facility agent reports) | 1 (278) | Medium | Unknown (1 study) | Indirect | Precise | MICA | Insufficient
MICA vs. treatment as usual | Substance use (urinalysis) | 1 (278) | Medium | Unknown (1 study) | Direct | Imprecise | MICA | Insufficient
IDDT vs. treatment as usual in the community | Mental health service use upon release (administrative records) | 2 (310) | Medium | Consistent | Indirect | Imprecise | IDDT (MIOCTP and high-fidelity IDDT) | Low
IDDT vs. treatment as usual | Mental health service use during incarceration (administrative records) | 2 (406) | Medium | Consistent | Indirect | Imprecise | IDDT (MIOCTP and MICA) | Low
MICA vs. treatment as usual | Institutional infractions (time in segregation, conduct reports) | 1 (278) | Medium | Unknown (1 study) | Direct | Imprecise | MICA | Insufficient

IDDT = integrated dual diagnosis treatment; MICA = mentally ill chemical abuser; MIOCTP = Mentally Ill Offender Community Transition Program; SOE = strength of evidence

One dual-diagnoses treatment trial reported change in psychiatric symptoms.81 This trial, Chandler and Spicer, reported the mean number of crisis visits per treatment group as well as the percentage of participants who experienced a crisis during the study followup period. The mean number of crisis visits was significantly lower among participants receiving high-fidelity IDDT compared with the number of crisis visits in the treatment-as-usual group (2.10 [4.59] vs. 3.32 [6.95], p=0.004). A lower percentage of patients experienced any crisis, although this did not reach statistical significance. See Table F10 in Appendix F for more information.

Two trials reported on psychiatric hospitalizations. Chandler and Spicer found that those receiving high-fidelity IDDT experienced fewer days in a psychiatric hospital than those in the treatment-as-usual group.81 Van Stelle and Moberg also reported psychiatric hospitalizations, operationalized as a documented institutional transfer to a mental health facility in the case files. They found that participation in the MICA therapeutic community led to fewer hospitalizations than treatment as usual (20.77 percent vs. 43.00 percent, p=0.000).82 See Table F11 in Appendix F for more information.

The Van Stelle and Moberg trial reported level of function as measured by appropriate housing, existence of an adequate social support system, and the observation that the individual appeared “stable,” all based on agent reports; it was the only trial to report on these parameters.82 MICA therapeutic community clients were more often rated as having adequate housing than participants treated as usual (83 percent vs. 79 percent) and as stable (58 percent vs. 44 percent), and MICA therapeutic community clients were rated the same as treatment-as-usual clients on presence of a social support system (76 percent vs. 76 percent), although none of these differences reached statistical significance. See Table F12 in Appendix F for more detail.

The Van Stelle and Moberg study was also the only trial to report medication adherence.82 Clients in MICA therapeutic community were more likely than participants in the treatment-as-usual arm to take their medications consistently, based on agent reports (58 percent vs. 34 percent, p=0.005). See Table F13 in Appendix F for more detail.

For substance abuse, Van Stelle and Moberg used self-reported, 3-month abstinence rates (63 percent MICA vs. 49 percent treatment as usual) and positive urinalysis rates (12 percent MICA vs. 15 percent treatment as usual); they both favored the MICA therapeutic community group, but the differences did not reach statistical significance.82 See Table F14 in Appendix F for more information.

Mental health service use upon release from incarceration was reported by both Theurer and Lovell and Chandler and Spicer. Theurer and Lovell found more mental health service use among clients in MIOCTP than among clients receiving treatment as usual.78 However, because this comparison was to a larger control group than the original matched sample, we did not calculate an effect size estimate.

Chandler and Spicer found high-fidelity IDDT increased service use more than treatment as usual.81 Seventy-seven percent of clients in IDDT received services within 60 days of release versus 18 percent of clients given treatment as usual (p=0.000). A similar result was found for outpatient medication service, with 83 percent of clients in IDDT and 62 percent of clients in the treatment-as-usual group receiving these services (p=0.01). See Table F20 in Appendix F for more detail.

Theurer and Lovell also reported that clients in MIOCTP received 20 hours of service while in prison compared with 0.7 hours in the comparison group.78 No calculation of a difference in effect size is presented because this outcome was not based on the matched control group, but on a larger unmatched “control” cohort. In the Van Stelle and Moberg trial, 45 percent of clients in a MICA therapeutic community versus 29 percent of the treatment-as-usual group accessed institutional mental health services while in prison (p=0.03).82 No difference by group membership was evident in terms of in-prison medication monitoring (96.2 percent and 94.0 percent, p=0.39). See Table F17 in Appendix F for more information.

The Van Stelle and Moberg study was the only trial to report institutional infractions.82 The investigators measured infractions in six different ways: percentage in segregation, average days in segregation, percentage with a minor conduct disorder, average number of subjects with a minor conduct report, percentage with major conduct reports, and average number of major conduct reports. Because the authors did not present any measure of variance for average days in segregation or average number of major or minor conduct reports, we could not calculate the effect size for these three measures. However, for the remaining three measures (percentage in segregation, percentage with a minor conduct disorder, and percentage with a major conduct disorder) a trend was evident for clients in a MICA therapeutic community to have fewer institutional infractions than clients receiving treatment as usual, although not all differences reached statistical significance. See Table F18 in Appendix F and for more information.

#### Applicability

On the whole, the three studies that enrolled patients with dual diagnoses to test the efficacy of comprehensive co-occurring disorders treatment enrolled non-Caucasian, middle-aged men, between 36 and 50 years of age.78,81,82

In two of the three trials, about 40 percent had a current or prior violent conviction.78,82 In the third trial, Chandler and Spicer, participants seem to have had less criminal justice involvement because the inclusion criteria required only that subjects had two or more jail episodes in the past 2 years or 90 days in jail.81 The rate of co-occurring personality disorders varied from study to study. Thus, the findings presented here may be applicable only to this subset of inmates. See Tables E9 and E10 in Appendix E for more detail.

### Forensic Specialist Versus Generalist Treatments

#### Description of Studies

Two trials, Coid and colleagues and Solomon and Draine, describe treatments administered by forensic specialists compared with treatments administered by general mental health staff.80,83 All subjects in the Coid and colleagues trial received standard-of-care treatment in a medium-secure unit of a psychiatric hospital. Upon release, individuals received either forensic specialist psychiatric care or mental health generalist care in the community for an average of a little more than 6 years.80

In the Solomon and Draine trial, subjects were assigned to one of three conditions: mental health service in jail and Assertive Community Treatment (ACT) upon release, forensic specialist services in jail and after release, or mental health service in jail followed by intensive case management brokered services.83 Subjects in the ACT treatment arm had case management services available 24 hour per day, 7 days a week, if needed. They also received assistance with housing, daily living and coping skills, locating resources, and supportive services for their family members. Participants in the Solomon and Draine study were observed for 1 year.

No ancillary treatments were reported by either of these studies. Treatment fidelity was noted to be poor in the Solomon and Draine study.83 Coid and colleagues did not comment on treatment fidelity.80 See Tables E7 and E8 in Appendix E for these and other treatment characteristics.

Subjects in the Solomon and Draine study were jail inmates due to be released in 4–6 weeks with a major mental illness, functional limitations, no housing upon release, and recent mental health service use.83 Participants in the Coid and colleagues trial were in a medium-secure forensic psychiatric service at the time of enrollment.80 No other details were provided. See Tables E9 and E10 in Appendix E for more information.

The two trials enrolled subjects in their late 20s to early 30s. Coid and colleagues did not report the ethnic breakdown of study participants,80 but 30 percent of those enrolled in the Solomon and Draine trial were Caucasian.83 Between 14 percent and 27 percent of the sample was female. Education levels in the Solomon and Draine study were low, with two-thirds of participants not completing high school. Coid and colleagues did not report a measure of literacy or education level attained.

Solomon and Draine did not report on the percentage of participants with convictions for violent crimes or Medicaid enrollment upon study entry. However, their study subjects were serving an average of 9.5-month terms during the study period.83 Approximately 50 percent of those in the Coid and colleagues trial had a history of or a current violent-crime conviction.80 Neither study reported on felony conviction status. See Tables E9 and E10 in Appendix E for more detail.

Participants in these specialist-versus-generalist trials had disease diagnoses based on clinical files using criteria from International Statistical Classification of Diseases and Related Health Problems, 10th Revision and Diagnostic and Statistical Manual of Mental Disorders, third edition, revised. The majority of participants in each trial had a diagnosis of schizophrenia or schizoaffective disorder. Based on clinical charts, a little more than half of subjects in the Solomon and Draine study had substance use disorders,83 and about 25 percent of Coid and colleagues study participants had alcohol or substance dependence.80 It is unclear to what extent these groups overlapped. Solomon and Draine did not report rates of co-occurring personality disorder, but 16 percent of Coid’s sample had a co-occurring antisocial personality disorder. See Table E10 in Appendix E for further detail.

#### Findings

Solomon and Draine measured change in psychiatric symptoms, substance abuse, and quality of life.83 Coid and colleagues did not report these outcomes. Solomon and Draine note that these outcome variables were dropped from the discriminant analysis because they did not add to the model’s predictive power. See Tables F10, F14, and F15 in Appendix F for more information.

Coid and colleagues reported psychiatric hospitalizations,80 and for readmissions, found no difference between treatment groups once potential confounders were controlled for. See Table F11 in Appendix F for more detail.

The Coid and colleagues study was the sole study to present findings on completed suicide: the authors found no difference between participants treated by forensic specialists and those treated by mental health generalists in completed suicide rates (10/409 (2.4 percent) vs. 20/652 (3.1 percent), p=0.55). See Table F16 in Appendix F and Table 17 below for additional detail.

Table 17 Strength-of-evidence grade for studies assessing specialist versus generalist treatment for Key Question 2

Comparison | Outcome | Number of Studies (Number of Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Direction of Effect | SOE Grade
ACT vs. forensic specialist vs. treatment as usual | Psychiatric symptoms | 1 (176) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
ACT vs. forensic specialist vs. treatment as usual | Substance abuse | 1 (176) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
ACT vs. forensic specialist vs. treatment as usual | Quality of life | 1 (176) | Medium | Unknown (1 study) | Direct | Imprecise | — | Insufficient
Forensic specialist vs. general MH services | Completed suicide | 1 (1,061) | Medium | Unknown (1 study) | Direct | Imprecise | Forensic specialist | Insufficient
Forensic specialist vs. general MH services | Psychiatric hospitalizations | 1 (1,061) | Medium | Unknown (1 study) | Direct | Imprecise | Forensic specialist | Insufficient

ACT = Assertive Community Treatment; MH = usual mental health services; SOE = strength of evidence

#### Applicability

The two trials that compared treatment provided by a specialist versus treatment by a generalist enrolled mostly males with an SMI in their early to mid-30s. In the Coid and colleagues trial, more than 40 percent had a violent criminal history.80 Participants in the Solomon and Draine trial were incarcerated, on average, 9.5 months, suggesting they, too, had a significant criminal history.83 Between 25 percent and 50 percent of enrollees in these trials had a substance abuse disorder and about 10 percent of the subjects in the Coid and colleagues study had a co-occurring diagnosis of antisocial personality disorder. Solomon and Draine did not report that patient characteristic. The findings presented here may be applicable only to this subset of inmates. See Tables E9 and E10 in Appendix E for more detail.

### Interpersonal Therapy Versus Psychoeducation

#### Description of Study

The last trial, Johnson and Zlotnick, compared IPT with psychoeducation.35 Participants in the IPT group attended manualized group treatment sessions three times per week for 8 weeks while incarcerated and 6 weekly postrelease individual sessions. IPT sessions targeted such areas as disrupted relationships with family and friends and coping with loss. Participants in the psychoeducation group received attention-matched, manualized psychoeducation sessions which focused on teaching participants about mental health issues and their relationship to substance abuse, providing medication-specific information, and about resources available in the community. Participants were observed for 3 months after treatment.

Subjects in the Johnson and Zlotnick trial received standard-of-care substance-abuse treatment in prison in addition to receiving the study treatment, and more than half of all subjects were on antidepressants.35 Treatment fidelity was noted to be very high in this trial. See Tables E7 and E8 in Appendix E for these and other treatment characteristics. Subjects were prison inmates due to be released in 10–24 weeks with both major depressive disorder and substance abuse diagnoses. The study enrolled female subjects in their mid-30s, the majority of whom were unmarried and Caucasian. The authors did not report patient education level, but 74 percent had an annual income of less than $10,000.

Johnson and Zlotnick did not report the percentage of participants with convictions for violent crimes, but the median number of arrests was 4 and 6 in the psychoeducation and IPT arms, respectively.35 This study did not report on felony conviction status or Medicaid enrollment upon study entry. See Tables E9 and E10 in Appendix E for more detail.

Participants had disease diagnoses based on the Structured Clinical Interview for Diagnostic and Statistical Manual of Mental Disorders Axis I disorders and for substance-use disorders. All participants had a primary (not substance induced) diagnosis of major depressive disorder and a substance use disorder. Co-occurring personality disorders, including borderline personality disorder and antisocial personality disorder, were present in a quarter to one-half of study subjects.35 See Table E10 in Appendix E for further detail.

#### Findings

Johnson and Zlotnick measured change in psychiatric symptoms and substance abuse.35 They reported that by the 3-month followup, both groups experienced a reduction in their depressive symptoms as measured by the mean HRSD, with no difference by treatment group (15.8 [SD, 11.7] and 12.0 [SD, 12.3] for the IPT and psychoeducation groups, respectively). Likewise, the two groups experienced similar rates of substance-abuse relapse after being release from incarceration (9/19 [47 percent] and 6/19 [32 percent] for the IPT and psychoeducation groups, respectively). See Tables F10 and F14 in Appendix F and Table 18 below for more information.

Table 18 Strength-of-evidence grade for studies assessing interpersonal therapy versus psychoeducation treatment for Key Question 2

Comparison | Outcome | Number of Studies (Number of Patients) | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
IPT vs. psychoeducation | Psychiatric symptoms, substance abuse | 1 (38) | Low | Unknown (1 study) | Direct | Imprecise | — | Insufficient

IPT = interpersonal therapy; SOE = strength of evidence

#### Applicability

The single trial that compared IPT with psychoeducation enrolled women in their mid-30s with dual diagnoses of major depressive disorder and substance abuse.35 They had a median of five prior arrests, and from 25 percent to 50 percent had a co-occurring personality disorder. The findings presented here may be applicable only to this subset of inmates. See Tables E9 and E10 in Appendix E for more detail.