# References

1 Torrey EF, Kennard AD, Eslinger D, et al. More mentally ill persons are in jails and prisons than hospitals: a survey of the States. Alexandria, VA. National Sheriffs’ Association, Treatment Advocacy Center. 2010. May. www.treatmentadvocacycenter.org/storage/documents/final_jails_v_hospitals_study.pdf.
2 Dickson KK, Sigurdson C, Miller PS. Improving psychiatric care in the Minnesota Corrections System: the Minnesota Psychiatric Society and the Minnesota Department of Corrections engage in ongoing dialogue. St. Paul (MN). Minnesota Psychiatric Society. www.mnpsychsoc.org/2006%20DOC%20Paper.
3 James DJ, Glaze LE. Bureau of Justice Statistics special report: mental health problems of prison and jail inmates. Washington (DC). U.S. Department of Justice. 2006. Sep. http://bjs.ojp.usdoj.gov/content/pub/pdf/mhppji.pdf.
4 State estimates of adult mental illness In: National survey on drug use and health. [database online]. Rockville (MD). Substance Abuse and Mental Health Services Administration. 2011. Oct. 6. http://oas.samhsa.gov/2k11/078/WEB_SR_078_HTML.pdf. Accessed October 7, 2011.
5 Abramsky S, Fellner J. Ill-equipped: U.S. prisons and offenders with mental illness. New York (NY). Human Rights Watch. 2003. 223 p. www.hrw.org/en/reports/2003/10/21/ill-equipped.
6 Sirotich F. The criminal justice outcomes of jail diversion programs for persons with mental illness: a review of the evidence. J Am Acad Psychiatry Law. 2009;37(4):461-72. [pmid: 20018995].
7 Veysey BM, Bichler-Robertson G. Providing psychiatric services in correctional settings. Health status of soon-to-be released inmates, vol. 2, Report to Congress. Chicago. National Commission on Correctional Health Care. 2002.
8 Baillargeon J, Hoge SK, Penn JV. Addressing the challenge of community reentry among released inmates with serious mental illness. Am J Community Psychol. Dec. 2010;46(3–4):361-75. [pmid: 20865315].
9 Standards for health services in jails. Chicago. National Commission on Correctional Health Care. 2008.
10 Steadman HJ, Veysey BM. Providing services for jail inmates with mental disorders. Nat Inst Just Res Brief. Jan. 1997:1-12. www.ncjrs.gov/pdffiles/162207.pdf.
11 Prevalence of serious mental illness among US adults by age, sex, and race. National Institute of Mental Health. [internet]. Bethesda (MD). National Institutes of Health. www.nimh.nih.gov/statistics/SMI_AASR.shtml. Accessed November 7, 2011.
12 Lovell D, Gagliardi GJ, Peterson PD. Recidivism and use of services among persons with mental illness after release from prison. Psychiatr Serv. Oct. 2002;53(10):1290-6. http://ps.psychiatryonline.org/article.aspx?articleID=87162. [pmid: 12364677].
13 Cloyes KG, Wong B, Latimer S, et al. Time to prison return for offenders with serious mental illness released from prison. A survival analysis. Crim Justice Behav. Feb. 2010;37(2):175-87. http://cjb.sagepub.com/content/37/2/175.abstract.
14 Morrissey JP, Dalton KM, Steadman HJ, et al. Assessing gaps between policy and practice in Medicaid disenrollment of jail detainees with severe mental illness. Psychiatr Serv. Jun. 2006;57(6):803-8. [pmid: 16754756].
15 Hoge SK, Buchanan AW, Kovasznay BM, Roskes EJ. Outpatient services for the mentally ill involved in the criminal justice system A report of the Task Force on Outpatient Forensic Services. Arlington, VA. American Psychiatric Association. October. 2009. www.psych.org/TFR200921.
16 Edens JF, Peters RH, Hills HA. Treating prison inmates with co-occurring disorders: an integrative review of existing programs. Behav Sci Law. Autumn. 1997;15(4):439-57. [pmid: 9433747].
17 O’Reilly R, Bishop J, Maddox K, et al. Is telepsychiatry equivalent to face-to-face psychiatry? Results from a randomized controlled equivalence trial. Psychiatr Serv. Jun. 2007;58(6):836-43. [pmid: 17535945].
18 Sanchez-Meca J, Marin-Martinez F, Chacon-Moscoso S. Effect-size indices for dichotomized outcomes in meta-analysis. Psychol Methods. Dec. 2003;8(4):448-67. [pmid: 14664682].
19 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2011. Aug. Chapters available at www.effectivehealthcare.ahrq.gov.
20 Morgan RD, Flora DB, Kroner DG, et al. Treating offenders with mental illness: a research synthesis. Law Hum Behav. Feb. 2012;36(1):37-50. [pmid: 22471384].
21 Martin MS, Dorken SK, Wamboldt AD, et al. Stopping the revolving door: a meta-analysis on the effectiveness of interventions for criminally involved individuals with major mental disorders. Law Hum Behav. 2011. Mar. 5. Epub ahead of print.
22 Griffiths EV, Willis J, Spark MJ. A systematic review of psychotropic drug prescribing for prisoners. Aust N Z J Psychiatry. May. 2012;46(5):407-21. [pmid: 22535291].
23 Huband N, Ferriter M, Nathan R, et al. Antiepileptics for aggression and associated impulsivity. Cochrane Database Syst Rev. 2010;(2):CD003499. [pmid: 20166067].
24 Nagi C, Davies J. Addressing offending risk in low secure mental health services for men: a descriptive review of available evidence. Br J Forensic Pract. Feb. 2010;12(1):38-47.
25 Sacks S, McKendrick K, Sacks JY, et al. Modified therapeutic community for co-occurring disorders: single investigator meta analysis. Subst Abuse. Jul. 2010;31(3):146-61. [pmid: 20687003].
26 Caring for individuals with schizophrenia in correctional settings and beyond. Chicago (IL). National Commission on Correctional Health Care. 2009.
27 Federal Bureau of Prisons. Management of major depressive disorder. Federal Bureau of Prisons clinical practice guidelines. Washington (DC). U.S. Department of Justice. 2009. Aug. www.bop.gov/news/medresources.jsp.
28 Improving outcomes for people with mental illnesses under community corrections supervision: a guide to research-informed policy and practice. New York. Council of State Governments Justice Center. 2009. http://consensusproject.org/downloads/community.corrections.research.guide.pdf.
29 Khalifa N, Saleem Y, Stankard P. The use of telepsychiatry within forensic practice: a literature review on the use of videolink. J Forensic Psychiatry Psychol. Mar. 2008;19(1):2-13.
30 Serious mental illness among adults. National Household Survey on Drug Abuse (NHSDA). [database online]. Rockville (MD). Substance Abuse and Mental Health Services Administration (SAMHSA). October. 18. 2002. www.oas.samhsa.gov/2k2/SMI/SMI.htm. Accessed November 7, 2011.
31 Fair care for all: humane treatment, just reform. Phoenix (AZ). American Civil Liberties Union of Arizona. www.acluaz.org/FairCareForAll. Accessed November 19, 2012.
32 Scott CL, editor. Handbook of correctional mental health. 2nd ed. Arlington (VA). American Psychiatric Publishing, Inc. 2010.
33 Hartwell SW, Fisher WH, Deng X. The impact of regionalization on reentry service outcomes for individuals with severe mental illness. Psychiatr Serv. Mar. 2009;60(3):394-7. [pmid: 19252055].
34 Woodson R. Security and patient management in a forensic hospital. New Dir Ment Health Serv. 1996;(69):35-42. [pmid: 8935821].
35 Johnson JE, Zlotnick C. Pilot study of treatment for major depression among women prisoners with substance use disorder. J Psychiatr Res. Sep. 2012;46(9):1174-83. [pmid: 22694906].
36 Jones C, Hacker D, Cormac I, et al. Cognitive behaviour therapy versus other psychosocial treatments for schizophrenia. Cochrane Database Syst Rev. 2012;4:CD008712. http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008712.pub2/pdf. [pmid: 22513966].
37 Eisenberg JM. Second-generation antidepressants for treating adult depression: an update. [internet]. Houston (TX). Baylor College of Medicine. 2007. www.ncbi.nlm.nih.gov/books/NBK99902/pdf/clindep2.pdf.
38 First-Generation Versus Second-Generation Antipsychotics in Adults: Comparative Effectiveness. Comparative Effectiveness Review No. 63. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021.) AHRQ Publication No. 12-EHC054-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. Aug. www.ncbi.nlm.nih.gov/books/NBK107254.
39 Gaynes BN, Lux LJ, Lloyd SW, et al. Nonpharmacologic interventions for treatment-resistant depression in adults. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2011. Sep. (Comparative Effectiveness Reviews; no. 33). [pmid: 22091472].
40 Drake RE, Mueser KT, Brunette MF. Management of persons with co-occurring severe mental illness and substance use disorder: program implications. World Psychiatry. Oct. 2007;6(3):131-6. [pmid: 18188429].
41 Lipsey MW, Landenberger NA, Wilson SJ. Effects of cognitive-behavioral programs for criminal offenders. Campbell Syst Rev. Aug. 9. 2007;6:1-27.
42 Robins CJ, Chapman AL. Dialectical behavior therapy: current status, recent developments, and future directions. J Personal Disord. Feb. 2004;18(1):73-89. [pmid: 15061345].
43 Pinta ER, Taylor RE. Quetiapine addiction. Am J Psychiatry. Jan. 2007;164(1):174-5. [pmid: 17202569].
44 Waters BM, Joshi KG. Intravenous quetiapine-cocaine use (“Q-ball”). Am J Psychiatry. Jan. 2007;164(1):173-4. [pmid: 17202567].
45 Baillargeon J, Black SA, Contreras S, et al. Anti-depressant prescribing patterns among prison inmates with depressive disorders. Washington (DC). U.S. Department of Justice. April. 2002.
46 Co-occurring disorders: integrated dual disorder treatment. [internet]. St. Paul (MN). Minnesota Department of Human Services. 2009. Aug. 12. www.dhs.state.mn.us/main/idcplg?IdcService=GET_DYNAMIC_CONVERSION&RevisionSelectionMethod=LatestReleased&dDocName=id_028650. Accessed July 8, 2011.
47 Integrated treatment for co-occurring disorders evidence-based practices (EBP) kit. [CD-ROM/DVD version] In: [internet]. Rockville (MD). Substance Abuse & Mental Health Services Administration (SAMHSA). 2010. Jan. http://store.samhsa.gov/product/Integrated-Treatment-for-Co-Occurring-Disorders-Evidence-Based-Practices-EBP-KIT/SMA08-4367. Accessed October 11, 2012.
48 What is a modified therapeutic community?. [internet]. Butte (MT). Community Counseling, and Correctional Services, Inc. (CCCS). www.cccscorp.com/modthercom2.htm. Accessed July 8, 2011.
49 Morgan RD, Patrick AR, Magaletta PR. Does the use of telemental health alter the treatment experience? Inmates’ perceptions of telemental health versus face-to-face treatment modalities. J Consult Clin Psychol. Feb. 2008;76(1):158-62. [pmid: 18229993].
50 Hartwell SW. Comparison of offenders with mental illness only and offenders with dual diagnoses. Psychiatr Serv. Feb. 2004;55(2):145-50. [pmid: 14762238].
51 Draine J, Angell B. Critical time intervention for prison and jail reentry: policy brief. New Brunswick (NJ). Center for Behavioral Health Services & Criminal Justice Research. 2008. Oct. www.cbhs-cjr.rutgers.edu/pdfs/10082008Policy_Brief.pdf.
52 Brun C, Rapp RC. Strengths-based case management: individuals’ perspectives on strengths and the case manager relationship. Soc Work. Jul. 2001;46(3):279-88.
53 Healey KM. Case management in the criminal justice system. Washington (DC). National Institute of Justice. February. 1999. www.ncjrs.gov/pdffiles1/173409.pdf.
54 Brown KA. Assertive community treatment: a reentry model for seriously mentally ill offenders. Columbus (OH). Ohio Department of Rehabilitation. 2003. Jun. www.sconet.state.oh.us/Boards/ACMIC/resources/assertive.pdf.
55 Forensic Assertive Community Treatment (FACT) resiliency and disease management outcome measure guidelines. (FACT fidelity scale). Houston (TX). Mental Health and Mental Retardation Authority of Harris County. 2006. Apr. 27. www.mhmraharris.org/LocalPlan/documents/7-FACTOutcomeMeasureGuidelines.pdf.
56 Loveland D, Boyle M. Intensive case management as a jail diversion program for people with a serious mental illness: a review of the literature. Int J Offender Ther Comp Criminol. Apr. 2007;51(2):130-50. [pmid: 17412820].
57 Narine L, Yee DS, Einarson TR, et al. Quality of abstracts of original research articles in CMAJ in 1989. CMAJ. Feb. 15. 1991;144(4):449-53. [pmid: 1993292].
58 Pitkin RM, Branagan MA, Burmeister LF. Accuracy of data in abstracts of published research articles. JAMA. Mar. 24–31. 1999;281(12):1110-1. [pmid: 10188662].
59 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
60 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub 2011 Apr 3. [pmid: 21463926].
61 Sacks S, Sacks JY, McKendrick K, et al. Modified TC for MICA offenders: crime outcomes. Behav Sci Law. 2004;22(4):477-501. [pmid: 15282836].
62 Sullivan CJ, McKendrick K, Sacks S, et al. Modified therapeutic community treatment for offenders with MICA disorders: substance use outcomes. Am J Drug Alcohol Abuse. 2007;33(6):823-32. [pmid: 17994478].
63 Sullivan CJ, Sacks S, McKendrick K, et al. Modified therapeutic community treatment for offenders with co-occurring disorders: Mental health outcomes. J Offender Rehabil. 2007;45(1–2):227-47.
64 Sacks JY, Sacks S, McKendrick K, et al. Prison therapeutic community treatment for female offenders: Profiles and preliminary findings for mental health and other variables (crime, substance use and HIV risk). J Offender Rehabil. 2008;46(3–4):233-61.
65 Sacks JY, McKendrick K, Hamilton Z. A randomized clinical trial of a therapeutic community treatment for female inmates: outcomes at 6 and 12 months after prison release. J Addict Dis. Jul. 2012;31(3):258-69. [pmid: 22873187].
66 Rees-Jones A, Gudjonsson G, Young S. A multi-site controlled trial of a cognitive skills program for mentally disordered offenders. BMC Psychiatry. 2012;12(1):44. [pmid: 22607165].
67 Cullen AE, Clarke AY, Kuipers E, et al. A multi-site randomized controlled trial of a cognitive skills programme for male mentally disordered offenders: social-cognitive outcomes. Psychol Med. Aug. 2011;16:1-13. [pmid: 21733222].
68 Balbuena L, Mela M, Wong S, et al. Does clozapine promote employability and reduce offending among mentally disordered offenders. Can J Psychiatry. Jan. 2010;55(1):50-6. [pmid: 20113544].
69 Martin A, O’Driscoll C, Samuels A. Clozapine use in a forensic population in a New South Wales prison hospital. Aust N Z J Psychiatry. Feb. 2008;42(2):141-6. [pmid: 18197509].
70 Tavernor R, Swinton M, Tavernor S. High-dose antipsychotic medication in maximum security. J Forensic Psychiatry. Apr. 2000;11(1):36-48.
71 Beck NC, Greenfield SR, Gotham H, et al. Risperidone in the management of violent, treatment-resistant schizophrenics hospitalized in a maximum security forensic facility. J Am Acad Psychiatry Law. 1997;25(4):461-8. [pmid: 9460034].
72 Wilson GL. Psychotherapy with depressed incarcerated felons: a comparative evaluation of treatments. Psychol Rep. Dec. 1990;67(3 Pt 1):1027-41. [pmid: 2287655].
73 Beck depression inventory. 2nd edition. [internet]. Ft. Lauderdale (FL). Center for Psychological Studies. http://cps.nova.edu/~cpphelp/BDI2.html. Accessed September 12, 2006.
74 Mortimer AM. Symptom rating scales and outcome in schizophrenia. Br J Psychiatry Suppl. Aug. 2007;50:s7-14. Also available: http://bjp.rcpsych.org/content/191/50/s7.full.pdf. [pmid: 18019038].
75 Trauma Recovery and Empowerment Model (TREM). [internet]. Alexandria (VA). Mental Health America, Centers for Technical Assistance. www.ncstac.org/index.php?option=com_content&view=article&id=83%Atrauma-recovery-and-empowerment-model-trem&catid=38&Itemid=56. Accessed July 8, 2011.
76 Young CR, Bowers MB Jr, Mazure CM. Management of the adverse effects of clozapine. Schizophr Bull. 1998;24(3):381-90. [pmid: 9718630].
77 Cullen AE, Soria C, Clarke AY, et al. Factors predicting dropout from the Reasoning and Rehabilitation program with mentally disordered offenders. Crim Justice Behav. Mar. 2011;38(3):217-30.
78 Theurer G, Lovell D. Recidivism of offenders with mental illness released from prison to an intensive community treatment program. J Offender Rehabil. 2008;47(4):385-406.
79 Wenzlow AT, Ireys HT, Mann B, et al. Effects of a discharge planning program on Medicaid coverage of state prisoners with serious mental illness. Psychiatr Serv. Jan. 2011;62(1):73-8. [pmid: 21209303].
80 Coid JW, Hickey N, Yang M. Comparison of outcomes following after-care from forensic and general adult psychiatric services. Br J Psychiatry. Jun. 2007;190:509-14. [pmid: 17541111].
81 Chandler DW, Spicer G. Integrated treatment for jail recidivists with co-occurring psychiatric and substance use disorders. Community Ment Health J. Aug. 2006;42(4):405-25. [pmid: 16933087].
82 Van Stelle KR, Moberg DP. Outcome data for MICA clients after participation in an institutional therapeutic community. J Offender Rehabil. 2004;39(1):37-62.
83 Solomon P, Draine J. One-year outcomes of a randomized trial of case management with seriously mentally ill clients leaving jail. Eval Rev. Jun. 1995;19(3):256-73. http://erx.sagepub.com/content/19/3/256.abstract.
84 McLellan AT. Addiction Severity Index (ASI). [internet]. Bethesda (MD). National Institute on Alcohol Abuse and Alcoholism (NIAAA). http://pubs.niaaa.nih.gov/publications/Assesing%20Alcohol/InstrumentPDFs/04_ASI.pdf. Accessed May 21, 2012.
85 CMHSR measures collection: quality of life interview (QOLI). St Louis (MO). George Warren Brown School of Social Work at Washington University, Center for Mental Health Services Research (CMHSR). http://brownprojects.wustl.edu/CMHSRMeasures/h3.html. Accessed May 9, 2012.
86 Heilbrun K, DeMatteo D, Yasuhara K, et al. Community-based alternatives for justice-involved individuals with severe mental illness: review of the relevant research. Crim Justice Behav. Apr. 2012;39(4):351-419.
87 McKendrick K, Sullivan C, Banks S, et al. Modified therapeutic community treatment for offenders with MICA disorders: antisocial personality disorder and treatment outcomes. J Offender Rehabil. 2007;44(2–3):133-59.
88 Peck MC, Scheffler RM. An analysis of the definitions of mental illness used in state parity laws. Psychiatr Serv. Sep. 2002;53(9):1089-95. http://ps.psychiatryonline.org/cgi/reprint/53/9/1089. [pmid: 12221306].
89 Definition of serious mental illness (SMI) - adults (18 and older). [internet]. Oklahoma City (OK). Oklahoma Department of Mental Health and Substance Abuse. www.odmhsas.org/eda/advancedquery/smi.htm. Accessed July 6, 2011.
90 Institute of Medicine (US), Committee on Ethical Considerations for Revisions to DHHS Regulations for Protection, Prisoners Involved in Research. Gostin LO, Vanchieri C, Pope A, editors. Ethical considerations for research involving prisoners. Washington, DC. National Academies Press. 2007.
91 Mitchell TR, Braham LG. The psychological treatment needs of deaf mental health patients in high-secure settings: A review of the literature. Int J Forensic Ment Health. Apr. 2011;10(2):92-106.
92 Duncan EA, Nicol MM, Ager A, et al. A systematic review of structured group interventions with mentally disordered offenders. Crim Behav Ment Health. 2006;16(4):217-41. [pmid: 17143928].
93 Hartwell S Evaluating effectiveness of a statewide public mental health re-entry program Project number: 5RC1MH088716-02 Research Portfolio Online Reporting Tools (RePORT)[database online] Bethesda (MD) National Institutes of Health (NIH) http://projectreporter.nih.gov/pr_Prj_info_desc_dtls.cfm?aid=7941726&icde=13898463&ddparam=&ddvalue=&ddsub=&cr=1&csb=default&cs=ASC&print=yes Accessed September 25, 2012
94 Hartwell SW, Deng X, Fisher W, et al. Harmonizing databases? Developing a quasi-experimental design to evaluate a public mental health re-entry program. Eval Program Plann. Nov. 2012;35(4):461-72. [pmid: 22436598].
95 Gelles RJ. Critical time intervention (CTI) for men with mental illness leaving prison. Project no 5R01MH076068-05 [internet]. Bethesda (MD). National Institutes of Health (NIH). http://projectreporter.nih.gov/pr_Prj_info_desc_dtls.cfm?aid=7898558. Accessed September 19, 2012.