# Methods

## Review Team

A three-person team conducted the systematic review. Although each member of the team has a background in behavioral health and has worked with individuals with SMI and co-occurring substance use disorders, none of the members is currently working with or within the criminal justice system or any other organization(s) that may have an interest in this report. Each member of the team has experience performing systematic reviews of behavioral health and health care evidence.

Mental health clinicians, representatives from the criminal justice system, and policymakers from both the behavioral health and criminal justice fields were involved only as key informants and/or members of the TEP. These groups provided some guidance on the scope of the report and its Key Questions, reviewed the protocol, and answered any questions that arose during the process.

## Topic Nomination, Triage, Refinement, and Review Protocol

A patient advocacy group and a national organization for psychiatry nominated this topic in November 2010. Topic triage and refinement occurred between February 2011 and April 2011. Individuals involved in the triage and refinement process conducted a preliminary literature search to determine the feasibility of conducting a CER on this topic and devised a list of possible Key Questions. ECRI Institute received this CER assignment in June 2011.

We enlisted five key informants to assist with refining the Key Questions and determining the scope of the report. They included a physician from a national patient advocacy group, a doctoral-level social worker working in a correctional setting, a medical director of a State Medicaid agency, a methodologist with experience conducting systematic reviews on criminal justice topics, and the director of medical services for a State correctional system. The Key Questions were posted for public comment for a 4-week period ending February 15, 2012.

Following the public comment period, a TEP reviewed and further refined the protocol. The TEP was comprised of an associate director of a forensic fellowship program, a former mental health director for a State department of corrections, three Ph.D.-level professors teaching in the areas of social policy and correctional mental health, a State department of corrections health services director, two methodologists, and a professor of psychiatry, medicine, and law. The protocol was completed in April 2012.

## Search Strategy

Information professionals performing literature searches within the ECRI Institute EPC Information Center followed established guidelines and procedures as identified by the Director of the Information Center. Below is an overview of the search process; specific search strategies are listed in Appendix A.

Consistent with our evidence-based searching protocol, for all Key Questions, we searched 12 external and internal databases on the OVID SP platform using the one-search and deduplication features. The databases included MEDLINE^®^, PreMEDLINE^®^, Embase, the Cochrane Library (including the Central Register of Controlled Trials, the Cochrane Database of Methodology Reviews, and the Cochrane Database of Systematic Reviews), the Database of Abstracts of Reviews of Effects, the Health Technology Assessment Database, and the United Kingdom National Health Service Economic Evaluation Database. Searches were designed to identify unique reviews, trials, economic analyses, and technology assessments. Because this topic involves mental health and criminal justice issues, three additional databases were searched for this project: PsycINFO^®^ (OVID SP platform), National Criminal Justice Reference Service (NCJRS) Abstracts Service (publicly available Web site), and ProQuest Criminal Justice (ProQuest platform). Our searches covered the time period January 1, 1990, through April 1, 2012.

We identified search terms by: (1) reviewing relevant systematic reviews on similar topics identified by members of the research staff; (2) reviewing how other relevant studies are indexed, their subject heading terms, and their keywords; and (3) reviewing MeSH, EMTREE, PsycINFO, NCJRS, and ProQuest Criminal Justice indexes for relevant and appropriate terms. After reviewing these, we identified a combination of subject headings and keywords. Two team members and the medical librarian reviewed the search strategies developed using these terms. We applied a study-design filter to retrieve systematic reviews and comparative studies. Details (specific search terms and search strategies) are provided in Appendix A.

We mined Web sites for gray literature meeting our inclusion/exclusion criteria. We excluded dissertations and literature that was not available as a full report (i.e., conference abstracts, slide presentations). Sources of gray literature included Bazelon Center for Mental Health Law, The Campbell Collaboration, Center for Evidence-based Policy, Justice Center (The Council of State Governments), Justice Policy Center (Urban Institute), Mental Health Primary Care in Prison, National Institute of Corrections, National Institute of Justice, RAND Corporation and the Washington State Institute for Public Policy. Resources (both for gray literature and peer-reviewed journal literature) and search strategies were discussed with the TEP and supplemented according to their recommendations. See Table 2, below, for a complete list of gray literature sources.

Table 2 Gray literature sources

Organization | Web Site
Academy of Criminal Justice Sciences | www.acjs.org/
American Academy of Psychiatry and the Law | www.aapl.org/
American Correctional Association | www.aca.org/
American Correctional Association Annual Conference | www.aca.org/Conferences/Summer2011/home.asp
American Correctional Health Services Association | www.achsa.org/index.html
American Psychiatric Association | www.psych.org/
American Psychological Association | www.apa.org/
Bazelon Center for Mental Health Law | www.bazelon.org/
Bureau of Justice Assistance | www.bja.gov/Default.aspx
Bureau of Justice Statistics | http://bjs.ojp.usdoj.gov/
Bureau of Prisons | www.bop.gov/
Campbell Collaboration | www.campbellcollaboration.org/
Center for Behavioral Health Services & Criminal Justice Research (Rutgers, The State University of New Jersey) | www.cbhs-cjr.rutgers.edu/
Center for Evidence-based Policy (Oregon Health & Science University) | www.ohsu.edu/xd/research/centers-institutes/evidence-based-policy-center/index.cfm/
Cochrane Collaboration, College for Policy at George Mason University | http://cochrane.gmu.edu/about/projects-publications
Cochrane Justice Health Field | http://justicehealth.cochrane.org/welcome
Criminal Justice/Mental Health Consensus Project (this is from The Justice Center—see below) | http://consensusproject.org/
Department of Health (UK) | www.dh.gov.uk/en/Publicationsandstatistics/Publications/PublicationsLibrary/index.htm (Search the site with mental within prison prisons prisoner prisoners – 252 pubs)
HTAi (Health Technology Assessment international portal) | www.htai.org/index.php?id=579
International Association for Correctional and Forensic Psychology | www.ia4cfp.org/
Justice Center (The Council of State Governments) | http://justicecenter.csg.org/
Justice Policy Center at the Urban Institute | www.urban.org/justice/index.cfm
Mental Health Primary Care in Prison | www.prisonmentalhealth.org/home.html
National Alliance on Mental Illness | www.nami.org/
National Association of State Mental Health Program Directors | www.nasmhpd.org/
National Commission on Correctional Health Care | www.ncchc.org/
National Criminal Justice Reference Service | www.ncjrs.gov/
National Institute of Corrections | http://nicic.gov/
National Institute of Justice (Office of Justice Programs) | http://nij.gov/
National Institute of Mental Health | www.nimh.nih.gov/
National Institute on Alcohol Abuse and Alcoholism | www.niaaa.nih.gov/
National Institute on Drug Abuse | www.nida.nih.gov/nidahome.html
National Reentry Resource Center (from the Justice Center—see above) | www.nationalreentryresourcecenter.org/
National Research Council | www.nationalacademies.org/nrc/
President’s New Freedom Commission on Mental Health | No direct Web site: www.nami.org/Content/NavigationMenu/Inform_Yourself/About_Public_Policy/New_Freedom_Commission/Default1169.htm
Prison Talk | www.prisontalk.com
RAND Corp. Institute for Civil Justice | www.rand.org/icj.html
Reentry Policy Council (from the Justice Center—see above) | www.reentrypolicy.org/
Robert Wood Johnson Foundation | www.rwjf.org/
SEARCH | www.search.org/
Substance Abuse and Mental Health Services Administration (SAMHSA) | www.samhsa.gov/
SAMHSA’s National Registry of Evidence-based Programs and Practices | www.nrepp.samhsa.gov/
U.S. Department of Justice | www.justice.gov/
Washington State Institute for Public Policy | www.wsipp.wa.gov/

ECRI Institute’s medical librarian reviewed the initial literature search results. Using the Key Questions and inclusion/exclusion criteria identified by team members, the medical librarian assessed relevancy and retrieved results. Feedback from two team members and the Director of the Health Technology Assessment/EPC Information Center—including details regarding gaps in the search strategy as well as articles identified by the principal investigator but not retrieved by the searches—were integrated into the search strategy using key terms and subject headings. We reran the updated strategy in all identified databases. The medical librarian scanned additional results and assessed their relevancy. New results were downloaded and forwarded to the principal investigator for review. Hand searches of reference lists in identified articles were also reviewed for possible inclusion. We updated the search through August 20, 2012, during the peer-review period of the draft report.

## Inclusion and Exclusion Criteria

The inclusion criteria are listed below in separate categories pertaining to patient characteristics, study design, outcomes, and publication type.

### Patient Characteristics

For a study to be included, results for individuals with SMI had to be reported separately from results for individuals with other diagnoses, or at least 75 percent of the sample had to have a diagnosis of schizophrenia, schizoaffective disorder, bipolar disorder, or major depression. In cases in which the diagnoses were not clearly presented, the study author(s) must have described the population as having SMI or as having severe and persistent mental illness or other equivalent. We considered studies to address the dually diagnosed population if at least 75 percent of the subjects also had an alcohol/substance use diagnosis. For studies with less than a 75 percent rate of substance use disorders, unless the study specifically excluded individuals with alcohol/substance use, we considered the sample to be a “mixed” population.

Studies of individuals with a primary diagnosis of a mental disorder such as posttraumatic stress disorder or a personality disorder without SMI were not included in this report.

### Study Design

Randomized controlled trials (RCTs) were assessed first. If an insufficient number (less than 10) of RCTs were available to draw a conclusion to a Key Question for the most important mental health outcomes, we examined nonrandomized (prospective or retrospective) comparative trials. Studies must have either randomly assigned patients or facilities to treatments or used an analytic method to address selection bias, such as baseline matching on multiple characteristics, propensity scoring, or other analytic approach.

Studies must have had an active treatment comparator (including treatment as usual). Because symptoms of SMI tend to wax and wane over time, we did not include noncomparative studies, such as case series, in this report.

Studies must have enrolled an independent control group. We excluded studies in which subjects acted as their own controls, such as in a pre-post or crossover study design. Facility-versus-facility comparisons as well as within-facility comparisons that employed an independent historical control group were considered for inclusion.

Studies must have included at least five subjects in both treatment arms because the results of studies with very small patient groups are often not applicable to the general population.

Included studies must have observed patients for a minimum of 3 months. For many outcomes, a minimum of 3 months may be necessary to determine if the treatment is effective (e.g., time to relapse).

### Outcomes

Studies must have reported at least one of the mental health outcomes assessed in this report. Studies that reported only an intermediate mental health outcome, but no patient-oriented mental health outcomes, are discussed but not analyzed. For all outcomes, we considered data only from time points for which at least 50 percent of the originally enrolled participants contributed data. Subjective outcomes, such as psychiatric symptoms and quality of life, must have been measured using validated instruments.

### Publication Type

Studies must have provided a sufficient description of the treatment provided (e.g., duration, dosage) such that the treatment could be replicated by others. Basing conclusions about treatments that are inadequately described will not add to our knowledge base.

Studies must have been conducted in the United States or in another country (Canada, United Kingdom, Australia, and New Zealand) with a legal system and heritage (i.e., rule of law and common law) similar to the United States. This report is aimed at assessing the comparative effectiveness of interventions available within the United States or interventions that could be applied in the United States. Because of differences across nations in justice and health care systems, only studies likely to produce results that are generalizable to the United States are included.

Publications must have been peer-reviewed, full-length articles or conducted by one of the agencies identified in the description of gray literature sources in this protocol. Abstracts alone were not included because they typically do not include sufficient detail about experimental methods to permit an evaluation of study design and conduct, and they also may contain only a subset of the measured outcomes.57,58 Abstracts of randomized studies that did not subsequently appear as full-length articles were flagged for possible evidence of publication bias.

To capture the most relevant data, we included studies published on or after January 1, 1990. Studies published before 1990 are likely to describe procedures and treatments no longer in common use or outcomes and conditions that are not likely to predict current outcomes. An updated search was conducted while this report is under review.

To avoid double-counting patients when several reports of overlapping patients were available, only outcome data from the report with the largest number of patients were included. We included the data from a smaller report when it provided data on an outcome that was not provided by the largest report.

Studies must have been published in English. Because this report has been limited to studies conducted in English-speaking countries for reasons of applicability, we do not anticipate being at risk of language bias by further restricting to studies published in English.

## Study Selection

Two team members independently reviewed articles in duplicate at the abstract level. We obtained for full review any articles possibly meeting the inclusion criteria for at least one Key Question. In cases in which the two abstract-reviewers disagreed, the full article was retrieved. Two team members also independently reviewed all retrieved articles for inclusion; disagreements between the two reviewers about full-length article inclusion were resolved by discussion and consensus.

## Data Extraction

We abstracted the information on general study characteristics, patient characteristics, treatment characteristics, risk-of-bias items, and outcome data (see next section) from full articles meeting the inclusion criteria.

We used the DistillerSR^®^ Web-based systematic review software for abstract screening and data extraction. A second team member reviewed each team member’s data extraction. Also, because of the possibility of subjective interpretation, we judged the risk-of-bias items in duplicate. We resolved all discrepancies by discussion. The overall categories of information to be obtained from each study include the following:

General study characteristics. Author, publication year, country, setting (rural or urban, as well as jail, prison, forensic hospital, and incarceration-to-community transitional services), study design, and which Key Question(s) the study addressed.

Patient characteristics. Number of enrolled patients, age, sex, education, ethnicity, primary mental health diagnosis, presence of a co-occurring personality disorder, percentage with a substance abuse diagnosis, and prior criminal justice involvement.

Treatment characteristics. Treatment, duration of treatment, dosage/frequency, education/educational degree of treatment administrator, modality, compelled versus voluntary.

Risk of bias items. See the next section.

Outcome data. For each included outcome, we extracted the number of patients contributing data to each included time point. We extracted the numerical data needed to compute an effect size and its 95 percent confidence interval (CI) for all included outcomes for each study. These may include means, standard deviations, counts, proportions, results of authors’ statistical tests, or other statistical details, depending on what was reported.

Multiple publications of the same study (e.g., publications reporting subgroups, other outcomes, or longer followup) were identified by examining author affiliations, study designs, enrollment criteria, and enrollment dates.

## Quality (Risk-of-Bias) Assessment of Individual Studies

We assessed the risk of bias (i.e., internal validity) separately for each outcome and time point. The reason for outcome specificity is that some subjective outcomes are more susceptible to bias than others. The reason for time-point specificity is that longer followup often results in attrition or right-censoring, which may yield patients who are somewhat different from the full set of enrolled patients and also may introduce a systematic difference between the groups being compared.

For all included studies we assessed risk of bias using the items below. All of these items were selected from a pool of items typically used by this EPC for systematic reviews of controlled trials. Each of these items was answered as “Yes,” “No,” or “Not reported.” See Table 3 below.

Table 3 Risk-of-bias assessment

Item | Comment
Were patients randomly assigned to the study’s groups?
Was the process of assigning patients to groups made independently from physician/mental health care provider and patient preference?
For nonrandomized trials, did the study employ any other methods to enhance group comparability?
Was the comparison of interest prospectively planned?
Were the 2 groups treated concurrently?
Were those who assessed the patients’ outcomes blinded to the group to which the patients were assigned?
Was the outcome measure of interest objective and was it objectively measured? | We categorized hospitalization for serious mental illness, mental health service access, suicide, recidivism, and adverse events as objective outcomes. We categorized change in primary psychiatric symptoms and quality of life as subjective outcomes. For adherence to pharmacotherapy and avoidance of substance or alcohol use, we categorized it as objective if the patient had a blood or urine test.
Was the treatment applied consistently across study subjects and over time? | To ensure that all patients, even those enrolled later, receive the same treatment, (e.g., the original version vs. an updated version)
Was there a ≤5% difference between groups in ancillary treatment(s)?
Was there a ≤15% difference in the length of followup for the 2 groups?
Did ≥85% of enrolled patients provide data at the time point of interest?
Was there a ≤15% difference between groups in the percentage of patients who provided data at the time point of interest?
Was funding free of financial interest? | We answered “no” if the authors developed the treatment examined in the study.

We have categorized each study as “low,” “medium,” or “high” risk of bias using the following method:

To be considered low risk of bias, the study must receive a “yes” on ALL of the following conditions and have at least 50 percent of the other items on the checklist above answered “yes”:

- Randomized
- Blinded outcome assessors
- If NOT blinded outcome assessors (or NR blinded outcome assessors), then the outcome was objective
- Treatment applied consistently across patients and time
- ≤15 percent difference in length of followup between groups
- ≥85 percent of enrolled patients provided data to this time point
- ≤15 percent difference in data provision rates to this time point

To be considered high risk of bias, the study must receive a “no” on the first question and a “yes” on the second question below and have less than 50 percent of the other items on the checklist answered “yes”:

- Was the process of assigning patients to groups made independently from physician and patient preference?
- Was a nonblinded outcome assessor assessing a subjective outcome?

To be considered medium risk of bias, the study meets neither the criteria for low risk of bias nor the criteria for high risk of bias.

Two team members performed all risk of bias category assignments (as low, medium, or high) in duplicate and independently, with disagreements resolved by consensus.

## Data Synthesis

From each included study, we extracted all important information about study design, patients, and reported data. Because the populations, interventions, and outcome measures used were heterogeneous, they did not lend themselves to a pooled analysis, so we chose to explore the data using a qualitative synthesis. When data from a study permitted, we calculated individual study effect size estimates. The choice of effect size metric depended on whether reported outcomes were continuous or dichotomous. Pre-post treatment differences and between-group posttreatment differences in outcomes measured using continuous data (e.g., scores on psychological tests) were calculated as the standardized mean difference. We computed baseline adjusted values using a pre-post correlation of 0.5. For dichotomous outcomes, we used the odds ratio as the measure of effect size; values greater than 1 favored the experimental group, and values less than 1 favored the control group. For all effect size metrics, we computed 95 percent CIs using standard methods.

The results of our analysis along with additional analysis reported by the authors of the studies are reported in the findings sections under each Key Question. We used calculated effect size estimates to help determine the overall strength of evidence. See the next section for further details about our strength of evidence assessment.

For each outcome, an important consideration is the smallest difference between groups that can still be considered clinically significant (minimum important difference). This definition aids interpretation in two main ways: (1) to determine whether a statistically significant difference is clearly clinically significant, and (2) to determine whether a statistically nonsignificant difference is small enough to exclude the possibility of a clinically significant difference.

For quality of life, we used established values for a clinically significant difference (e.g., Short Form-36, mental health subscale—5 points).17 For all other outcomes assessed on a scale in this report, we defined the minimum important difference as an odds ratio of 1.39, which corresponds to a Hedges’ g of 0.2, using the formula recommended by Sánchez-Meca and colleagues.18 For suicide, any statistically significant difference met the standard of a clinically significant difference.

## Strength of the Body of Evidence

We assessed strength of evidence for each Key Question based on guidance from the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” from the Agency for Healthcare Research and Quality.59 We judged the evidence for each outcome reported according to risk of bias, consistency, directness, and precision. Because there was little variability in risk-of-bias assessments, we modified this approach slightly, looking to other domains to make a determination about the grade. We defined the evidence base as consistent if all trials found an effect in the same direction. We defined direct evidence as studies that reported the effect of treatment on a patient-oriented, rather than intermediate outcome. Because we decided against performing meta-analysis in this report, we considered an effect size to be precise if it was statistically significant in the included studies. We also factored in the number of trials and participants in making this determination. We graded the evidence as insufficient if there was only one trial addressing a particular outcome or if two trials reported inconsistent results for the same outcome. If there was sufficient evidence (at least two trials reporting a consistent conclusion), then we assigned a strength of evidence grade based on the number of included studies. We applied a low strength of evidence grade in cases in which only two trials reported an outcome. See Table 4 below.

Table 4 Strength-of-evidence grade for the body of evidence

Grade | Evidence-based Practice Center Program Definition | Operational Definition for This Report
High | High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of effect. | Four or more trials of any risk of bias reported a consistent and precise (narrow confidence interval) effect size estimate for a patient-oriented (direct) outcome.
Medium | Medium confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect. | Three trials with any risk-of-bias grade reported a consistent and fairly precise (fairly narrow confidence interval) effect size estimate for a patient-oriented (direct) outcome.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect | Two trials with any risk of bias grade reported consistent results on either a direct (patient-oriented) or indirect (intermediate) outcome.
Insufficient | Evidence is either unavailable or does not permit a conclusion. | No trials or only one trial reported an outcome or two trials reported inconsistent findings for the outcome.

## Applicability Assessment

As defined in the AHRQ Effective Health Care Program “Methods Guide for Comparative Effectiveness Reviews of Medical Interventions,” applicability is “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under ‘real-world’ conditions.”60 Applicability depends on context and cannot be assessed with a universal rating system.60

Assessment of the applicability of a body of evidence is a complex task and involves addressing a series of methodological questions. These questions include:

- What are the populations of interest and the “real world” conditions relevant to the stakeholders of this evidence report? From whose perspectives should the applicability of the evidence be evaluated? This CER potentially serves multiple stakeholders, such as clinicians, patients, families, and policymakers. Different stakeholders may have different populations of interest and different applicability issues for consideration.
- What factors may affect the applicability of a study? What factors need to be considered in the assessment of applicability? While the PICOTS (i.e., population, intervention, comparator, outcome, timing, and setting) approach may be used to identify these factors, some of the factors may have already been considered, at least in part, in the study inclusion/exclusion process.
- How would the impact of each of these factors be judged or graded? The answer to this question is not always straightforward. For example, it is difficult to judge the exact degree to which the findings of a study that included only patients of 55 years of age or older apply to a younger population. The judgment is often made on a subjective basis.
- How would the impact of these various factors be synthesized to reach a general conclusion about the applicability of an individual study? Studies included in evidence reviews may report different applicability-related data (e.g., different types of comorbidities) or report the same types of data (e.g., recidivism) in different ways (e.g., new offense, new incarceration).

Given these issues, we chose a practical approach to assessing the applicability of evidence for this evidence review. The goal of our assessment is to provide useful information to concerned stakeholders in judging whether the evidence is applicable to the population or conditions of their interest.

We first abstracted data from each included study on factors that may affect the applicability of the study. We primarily focused on factors in the three following areas that are most relevant:

- Population—demographic characteristics, comorbidity of substance abuse diagnosis, criminal history
- Intervention and comparators—pharmacologic, psychological, dual diagnoses, discharge planning with benefit assistance, and generalist-versus specialist-provided treatments; the comparator was usually standard of care
- Setting—place of incarceration, rural versus urban

Based on a review of the data abstracted, we narratively summarized any patterns reflected from these factors that could potentially affect the applicability of the evidence. Our narrative summaries are intended to draw stakeholders’ attention to potential applicability issues embedded in the evidence.

## Peer Review and Public Commentary

Experts in the mental health, criminal justice, law, and research methodology fields and individuals representing stakeholders and user communities were invited to provide external peer review of this CER. Manufacturers were invited to provide information on their products. AHRQ and an associate editor also provided comments. AHRQ posted the draft report on its Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.