# Introduction

## Definitions

For this evidence review, we define serious mental illness (SMI) as a diagnosis of schizophrenia, schizoaffective disorder, bipolar disorder, or major depression. Study populations classified as SMI or as having a severe and persistent mental illness are also included. Excluded are individuals with dementia, personality disorder, or mental retardation.

SMI offenders include those in jails (which house inmates who are awaiting adjudication of their cases or who are serving sentences of less than 1 year for minor offenses), prisons (which house inmates convicted of more serious crimes for longer durations), and forensic hospitals (often specialized units within State-run psychiatric hospitals that house offenders for varying lengths of time).

## Incidence and Prevalence

Overall prevalence estimates of SMI among incarcerated adults range from 15 percent to 25 percent, depending on the study and data source.1–3 Numerous reports indicate that individuals with SMI are over-represented in the criminal justice system. These estimates are three to five times as high as in the general population, in which the prevalence of SMI ranges from 5 percent to 8 percent.4 In its report on prisons and offenders with mental illness, the organization Human Rights Watch indicated that up to 19 percent of adults in State prisons have significant psychiatric or functional disabilities.5,11,30 The National Commission on Correctional Health Care reported the following prevalence estimates of mental illness in State prisons:5

- Major depression, 13.1 percent to 18.6 percent
- Schizophrenia or another psychotic disorder, 2.3 percent to 3.9 percent
- Bipolar disorder, 2.1 percent to 4.3 percent

Research conducted in the United States found that between 28 percent and 52 percent of those with SMI have been arrested at least once.6

### Treatment Requirements

Jails and prisons have a constitutional obligation to provide treatment to inmates with serious medical and psychiatric conditions.7 The case of Ruiz v. Estelle set forth minimum requirements for providing mental health services in the U.S. correctional system.8 To receive accreditation by the American Correctional Association and the National Commission on Correctional Health Care, an adult correctional facility must provide all inmates with standard mental health screening and crisis and suicide intervention. More specialized mental health treatment generally varies depending on type of facility (e.g., jail vs. prison) and level of security (e.g., minimum vs. maximum). However, the National Commission on Correctional Health Care and others recommend that all correctional facilities offer standard outpatient or inpatient mental health treatment, such as individual or group psychotherapy, psychotropic medication, or discharge planning.8,9

A 1997 study by Steadman and Veysey, however, indicated that few jails provide a range of services, with most providing only intake screening, mental health evaluations, and suicide prevention services (83 percent, 60 percent, and 73 percent, respectively, of 1,013 jails surveyed).10 Because prisons hold inmates for long periods of time, they generally provide a greater range of services than jails do. However, the type and extent of treatment provided varies from prison to prison depending on factors including regional location and funding. A survey of mental health services provided in U.S. prisons indicated that 77 percent provide access to inpatient care and 36 percent have specialized housing.11 According to Baillargeon and colleagues, the primary barrier to improving mental health treatment provided in adult correctional facilities is inadequate State funding.8 To meet the basic requirements for providing mental health services, many prisons outsource to for-profit companies that provide services with an eye towards cost containment.31

### Recidivism

Overall, offenders with mental illness have slightly higher rates of recidivism than do offenders without mental illness.12 One study reported that 64 percent of offenders who were mentally ill were rearrested within 18 months of release; in offenders without mental illness, the rate was 60 percent.12 Another study that observed offenders who were mentally ill for an average of 39 months after release into the community found that “renewed involvement in the criminal justice system was the norm,” with 41 percent being convicted of felonies, 61 percent being convicted of any crime, and 70 percent being convicted of new offenses or supervision violations.13

The literature suggests that recidivism among offenders with mental illness is largely associated with poor coordination of services and treatment upon release into the community.13 observed Most offenders with SMI are eligible for Medicaid or Medicare through Supplemental Security Income or Social Security Disability Insurance (during periods when they are not institutionalized).14 Some advocacy groups are concerned that terminating benefits during incarceration and waiting up to 90 days for benefits to be reinstated after release may contribute to treatment nonadherence and recidivism.14

High rates of incarceration and recidivism along with insufficient treatment options have led to considerable interest in improving the outcomes of offenders with SMI. A systematic review of the evidence on the comparative effectiveness of interventions intended to improve mental health and other outcomes of offenders with SMI could help individuals with SMI, family members, treatment providers, criminal justice administrators and staff, and, possibly, State and Federal policymakers make decisions about available treatment options.

This review is about interventions provided to offenders 18 years of age or older with SMI who are detained in a jail, prison, or forensic hospital or who are transitioning from one of these settings back to the community (e.g., returning to their home or a halfway house). This is an especially vulnerable population because “jails and prisons have cultures that often lead to maladaptive behaviors in offenders with SMI that subsequently undermine treatment” both in and out of incarceration settings.15

## Disease Burden

Overrepresentation in the criminal justice system of individuals who are mentally ill not only places considerable stress on the individuals, their families, and the community in general but also on the criminal justice system. Jails and prisons are generally not equipped to care for large numbers of inmates with SMIs. As a result, offenders with SMI place a substantial structural burden on the criminal justice system because of longer prison stays and additional demands on the prison staff. According to a report by the Treatment Advocacy Group, the main reason inmates who are mentally ill stay incarcerated longer than inmates who are not is that many find it difficult to understand and follow jail and prison rules.1 Thus, inmates with mental illness are more likely than other inmates to be charged with facility rule violations or infractions. For instance, in Washington State prisons, inmates with mental illnesses accounted for 41 percent of infractions but constituted 19 percent of the prison population.1

Because of their impaired thinking, inmates with SMI may be disruptive or aggressive and present unique management challenges within the jail or prison setting.1,32 Maladaptive behaviors exhibited by inmates with SMI range from physical and nonphysical assault (e.g., spitting, throwing urine) to disruptive behavior (e.g., setting fires, refusing to leave cell) to self-injurious behavior (e.g., cutting or mutilating self, threatening or attempting suicide). Managing these behaviors often places additional demands on custodial staff members who may feel underprepared to deal with such difficult behaviors. Maintaining safety and order requires custodial staff to work together and collaborate with mental health professionals.32

Studies have reported a wide range of substance-abuse rates among offenders with mental illness (10 percent to 90 percent).33 Offenders with co-occurring mental illness and substance use disorders present treatment challenges. In general, they have a poorer prognosis for involvement in treatment than individuals with a single disorder.16 Further, one study found that inmates involved in jail substance abuse treatment who had dual diagnoses had more pronounced difficulties than other inmates enrolled in substance abuse treatment in several areas of functioning, including employment, relationships, and medical problems and had lower baseline knowledge about substance abuse treatment principles and relapse-prevention skills.16

## Providing Mental Health Services to Offenders With Serious Mental Illness Who Are in an Incarceration Setting (Jail, Prison, Forensic Hospital)

Jails are locally operated facilities that typically provide pretrial detention and short-term confinement after sentencing (generally less than 1 year).7 Most arrestees are detained for brief periods usually lasting days or weeks. Mental health services provided in jails typically focus on identifying mental illness, crisis management (including suicide prevention), and short-term treatment. In their study of American jails, Steadman and Veysey found that the mental health services provided in jails varied depending on the size of the facility.10 Small jails typically offered little more than screening and suicide prevention, whereas some large jails offered a comprehensive array of services that included screening, evaluation, specialized housing, and psychotropic medication.

Prisons, which are correctional facilities that typically hold inmates for longer than a year, are operated by Federal and State governments or by private companies. The responsibility of providing mental health services in prisons varies from State to State. According to Veysey and Bichler-Robertson, in some states, “psychiatric care is provided under the auspice of State mental health facilities, and in others, under the auspice of the State corrections authority.”7 Mental health services in Federal and State prisons are frequently contracted out.

Because incarceration within a prison can last for years, prisons typically provide a greater range of mental health services than jails.7 The mental health services provided in prisons generally parallel those available in the community and may include psychological counseling, treatment of trauma-related symptoms, integrated treatment for co-occurring mental health and substance use disorders, and psychiatric medication management.32

Offenders with mental illness are sometimes found not guilty by reason of insanity, incompetent to stand trial, or are sentenced to serve time in a forensic hospital. A forensic hospital is often a unit within a State mental health hospital, which serves the general population. Forensic hospitals provide mental health treatment within an environment that must maintain security to prevent escapes, assaults, and self-injurious behavior.34 In cases in which a jail does not provide inpatient care or specialized housing, individuals in whom SMI has been diagnosed may be transferred to a forensic hospital while awaiting further sentencing.7

Applying mental health services in the jail or prison environment presents exceptional treatment challenges. For example, adults with SMI can take medications that require multiple doses throughout the day. Correctional facilities may not be designed to accommodate a variety of medication administration schedules. Additionally, group therapy sessions may be impractical in situations in which individuals who commit prison-rule infractions or who pose a safety risk are segregated from other prisoners.

### Interventions Used With Nonoffenders With Serious Mental Illness

There is a large literature base examining the interventions assessed in this report among nonoffenders. The following are a just few examples of what is known about these treatments.

Among psychotherapies, interpersonal therapy (IPT) is an evidenced-based treatment that has been shown to be effective in treating individuals with major depressive disorder living in the community.35 Limited evidence existed showing no difference in the effectiveness of cognitive behavior therapy (CBT) as adjunct therapy versus other adjunct talk therapies (psychoeducation, supportive therapy, group therapy, relaxation therapy, and family therapy) for individuals with schizophrenia living in the community. However, there was limited evidence suggesting that CBT may have a long-term advantage in helping patients deal with emotions and distressing feelings.36

In medical treatments, among patients with major depressive disorder, second-generation antidepressants had similar effectiveness but different side effects and times to onset of action.37 Among adults with schizophrenia, clozapine was more effective than chlorpromazine. Haloperidol had clinical effectiveness similar to aripiprazole, clozapine, risperidone, and ziprasidone. Among patients with bipolar disorder, haloperidol was more effective than ziprasidone.38 However, in those with treatment-resistant depression or treatment-resistant depression in bipolar disorder, electroconvulsive therapy was more effective than medication.39

A review of treatment programs for individuals with dual diagnoses found that a clear mission, active leadership, and ongoing supervision are critical components of a program’s success. No evidence favored one psychotherapy intervention over another, but long-term residential and peer-group interventions appeared to be effective treatment components.40

### Interventions Used in Incarceration Settings

#### Individual and Group Psychotherapy

Psychological therapies provided in jails, prisons, or forensic hospitals may include CBT (with or without criminal thinking curriculum) and dialectical behavior therapy (DBT). CBT aims to build cognitive skills and replace distorted cognitions (self-justificatory thinking, displacement of blame, schemas of dominance and entitlement) with noncriminal thought patterns.41 DBT was originally designed to treat chronically parasuicidal women with borderline personality disorder, but it has been adapted to other populations, including offenders with SMI. DBT combines the basic strategies of CBT with Eastern mindfulness practices.42

#### Pharmacologic Therapy

According to Scott, if a correctional facility houses inmates with SMI, antipsychotic, antidepressant, and mood-stabilizing medications must be included in the medication formulary.32 Further, “all correctional formulary policies must include a mechanism to access nonformulary medications on a case-by-case basis to ensure access to appropriate treatment for serious mental illness.”32 However, many correctional facilities limit access to certain medications based on their perceived abuse potential. In most correctional facilities, a psychiatrist and other mental health professionals must be involved in developing the institution’s formulary.

Most correctional formularies include both conventional (first-generation) and second-generation antipsychotics for treating schizophrenia, psychotic disorders, and psychotic symptoms. First-generation antipsychotics such as chlorpromazine (Thorazine^®^) and haloperidol (Haldol^®^) are available in generic form and are thus relatively inexpensive. However, most conventional antipsychotics are associated with severe and often painful movement disorders, such as dystonia (painful muscle spasms), akathisia (profound restlessness), and tardive dyskinesia (uncontrolled movement of various muscle groups usually around the face and mouth), which often interfere with patient medication adherence. Patients taking second-generation antipsychotic medications such as clozapine (Clozaril^®^) and olanzapine (Zyprexa^®^) have a lower risk of developing movement disorders, but the drugs are known to produce unwanted metabolic side effects including weight gain. Anecdotal evidence suggests that some of these drugs also carry the potential for abuse and diversion because of their sedating effects. This potentiality has led some correctional facilities to exclude them from their formularies.43,44

Many classes of antidepressants are available to treat major depression: tricyclic antidepressants (TCAs), monoamine oxidase inhibitors (MAOIs), and selective serotonin-reuptake inhibitors (SSRIs). A review at the Texas Department of Corrections found that more than 50 percent of inmates with depressive disorders were treated with TCAs, one-third with SSRIs, and about 20 percent were not being treated for their condition.45 However, case reports have raised questions about the potential of TCA abuse, primarily in individuals with dual diagnoses. MAOIs, such as phenelzine (Nardil^®^), can cause a hypertensive crisis if ingested with certain foods or over-the-counter medications. Thus, if used, TCAs and MAOIs require close monitoring, which presents an added challenge in correctional facilities.32 SSRIs are generally considered safer and have lower toxicity than TCAs and MAOIs. Mood stabilizers such as lithium and some anticonvulsant medications (e.g., divalproex [Depakote^®^], valproic acid [Depakene^®^]) are included in most prison formularies for treating bipolar disorder and schizoaffective disorder because these drugs carry no potential for abuse.

#### Specialized Housing

Specialized housing includes self-contained mental health units for caring for inmates with SMI who are unable to function in the general population.8 Specialized housing options vary and include inpatient care, short-term crisis beds, and long-term residential units.

#### Integrated Dual Disorder Treatment

With Integrated Dual Disorder Treatment (IDDT), the same treatment team treats addiction and SMI simultaneously. The substance abuse treatment is tailored to people with mental illness. Individuals are taught how mental health and substance abuse disorders interact. This approach uses CBT.46,47

#### Modified Therapeutic Community

Modified Therapeutic Community (MTC) is an intensive, long-term, residential treatment program that has been modified to meet the special needs and issues of a corrections population. The goal of MTC is to teach individuals how to live and function within the greater society and within their own families in a sober, prosocial manner. The program labels its users “family members” and assigns each person to a unit that staff refer to as a “family” or “community.”48 MTCs can be provided within a prison setting as well as in the community as an aftercare program once the inmate is released from prison.

#### Telemedicine

Telemedicine (i.e., telepsychiatry, telepsychology) is becoming an increasingly common mode of delivery for psychological and psychiatric services. Treatment is delivered by way of videoconferencing.49

## Providing Mental Health Services to Offenders With Serious Mental Illness Transitioning From Incarceration to the Community

Successful reentry into the community (e.g., family/home, halfway house) is a challenge for inmates with SMI or dual diagnoses.8 They are more likely than inmates without SMI to experience homelessness and are less likely to find employment. This is especially true for returning inmates with SMI and a co-occurring substance use disorder. A recent study assessing short-term, postrelease outcomes of prisoners with SMI only and those with SMI and substance abuse disorders found that the population with a dual diagnosis was more likely than the SMI-only population to experience homelessness and to be returned to correctional custody.50

Obtaining appropriate community mental health and other related services is often difficult for returning inmates with SMI. According to Baillargeon and colleagues, inadequate treatment and discharge planning take place during incarceration and too few mental health care programs are available upon release. Additionally, mainstream, community-based, mental health programs may be ineffective in meeting the diverse needs of returning inmates with SMI. Some community mental health programs may also be unwilling to provide services to those with a criminal history.8

### Examples of Interventions Provided When Inmates Are Transitioning to the Community

#### Discharge or Release Planning

Discharge planning has been defined as the process of “creating a continuum of care pertaining to mental health and substance abuse services as an inmate is released to the community.”8 The basic element of discharge planning should include the following actions: assessing the inmate’s clinical and social needs, writing a plan detailing the treatment and services required by the inmate, and identifying specific community providers and coordinating treatment with them. The extent of discharge planning may vary depending on the needs of the inmate, availability of resources to meet those needs, and incarceration setting (e.g., jail vs. prison, rural vs. urban setting). One important factor in successfully linking returning inmates with SMI to community mental health services is access to health benefits.8

#### Critical Time Intervention

Critical Time Intervention (CTI) is a three-phase treatment model that supports transition from institutional settings into community settings.51 The phases of treatment include transition, tryout, and transfer to care. Mental health practitioners designed CTI to prevent homelessness and other adverse outcomes in people with mental illness following discharge from hospitals, shelters, prisons, and other institutions. It combines several treatment models, including CBT, illness management, supported housing, IDDT, and motivational enhancement.

#### Case Management Interventions

Below are examples of some commonly used case management strategies.

##### Strengths-Based Case Management

The goal of strength-based case management is to build on a person’s successes so he or she develops a sense of personal empowerment. This treatment promotes the use of informal helping networks, offers assertive community involvement by case managers, and emphasizes the relationship between client and case manager.52

##### Standard Case Management

Standard case management follows a “service broker” model. It emphasizes assessment, planning, referral, and monitoring of functions without extensive outreach, linkage, or direct service contacts.53

#### Intensive Community Treatments

Below are examples of some commonly used intensive community treatments.

##### Assertive Community Treatment

Assertive community treatment (ACT) provides comprehensive (around-the-clock) community care to patients who are mentally ill, including access to a psychiatrist, nurse, substance abuse specialist, and case manager. The ratio of care is 10 patients to 1 staff member. ACT members provide medication; CBT, including issues of structuring time and handling activities of daily living; supported employment services; support and education of family members; and help with housing, transportation, or other client needs.54

##### Forensic Assertive Community Treatment

Forensic assertive community treatment (FACT) is a modification of ACT meant to reduce recidivism rates. The FACT team intervenes when clients are decompensating, to ensure they get appropriate mental health treatment before they recidivate.55

## Scope of Report and Key Questions

This report focuses on the comparative effectiveness of interventions provided to offenders with SMI, with or without a co-occurring substance use disorder, during incarceration in jail, prison, or forensic hospital or during transition from incarceration in these settings to the community. Transitional interventions are usually initiated within 3 months of an inmate’s release from incarceration and continued once he or she reenters the community.

In determining the scope of this report, we considered a number of programs designed to prevent or minimize incarceration. This included prebooking diversion interventions such as mobile crisis intervention teams or other interventions delivered at the point of contact with the police. We also considered postbooking strategies, such as mental health courts designed to divert offenders with SMI to a treatment environment in lieu of incarceration and court-ordered involuntary treatment intended to restore competency to stand trial.8 However, after discussions with our Technical Expert Panel (TEP), we decided against including these interventions so we could focus the report on those used during incarceration or during transition to the community.

Evidence-based Practice Center (EPC) reports and translation products produced for the Agency for Healthcare Research and Quality (AHRQ) are intended for use by patients, providers, administrators, researchers, and sometimes policymakers. This report and any AHRQ-sponsored derivative products have a broad target audience.

Two other comprehensive systematic reviews have been conducted on interventions for offenders with SMIs; however, neither review described the interventions assessed in their included studies and both conducted meta-analyses based on single treatment components (e.g., presence or absence of a homework component).20,21 Important goals of this comparative effectiveness review are to describe incarceration-based and incarceration-to-community interventions in a manner that would allow treatment providers to replicate effective treatments and to identify gaps in the scientific literature for future research in the field.

### Topic Development and Refinement

We posted four Key Questions for public comment on the Web site of the Effective Health Care Program from January 18, 2012, to February 15, 2012. Following the public comment period, we included our definition of SMI within the Key Questions. Based on discussions with members of the TEP for the report, we condensed what were originally Key Questions 1 and 2 and Key Questions 3 and 4 into two broader Key Questions that incorporate those with or without a substance abuse disorder. The Key Questions as currently written also reflect feedback from the panel on the importance of including jails as a treatment setting of interest in this report.

We further modified KQ2 to more clearly indicate the types of community-oriented interventions covered in this report. More specifically, it clarifies that we considered studies that describe a community treatment that is being provided to inmates with SMI who are returning to the community from incarceration. This does not include studies of community treatment provided for individuals who have been diverted out of the criminal justice system. We recognize that the types of interventions provided to these groups are likely to be similar. However, the intent of the interventions may differ depending on the population being served. For instance, diversion programs focus on reducing or eliminating involvement in the criminal justice system and replacing it with treatment, whereas reentry programs focus on community reintegration and reducing future involvement in the criminal justice system (i.e., recidivism or reincarceration).56

The final Key Questions are listed below. They are followed by the PICOTS outline (populations, interventions, comparisons, outcomes, timing, and settings), which clarifies the scope of each Key Question, and the analytic framework, which provides the same information in a pictorial format.

Key Question 1 (KQ1) What is the comparative effectiveness of interventions applied within a jail, prison, or forensic hospital setting for adults with SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a co-occurring alcohol/substance abuse diagnosis? Is there a difference in the comparative effectiveness of interventions based on the setting (jail, prison, forensic hospital) in which the interventions are provided?
Key Question 2 (KQ2) What is the comparative effectiveness of incarceration-to-community transitional interventions for adults with SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a co-occurring alcohol/substance abuse diagnosis? Is there a difference in the comparative effectiveness of interventions based on the setting (jail to community, prison to community, forensic hospital to community) in which the interventions are provided?

### Analytic Framework

The analytic framework (Figure 1) depicts the population, treatment, intermediate- and patient-oriented outcomes that are assessed in this report. On the left side of the figure we list the populations of interest: adults with SMI with or without a co-occurring alcohol or substance abuse diagnosis who are involved in one of the criminal justice system settings of interest. KQ1 compares interventions within an incarceration setting (i.e., jail, prison, or forensic hospital) or the same intervention applied across incarceration settings. KQ2 compares interventions provided during the transition from incarceration (i.e., jail, prison, or forensic hospital) to the community (e.g., home/family, halfway house). For KQ2, the comparisons are different interventions applied within an incarceration-to-community transitional setting, the same intervention applied across settings, or an incarceration intervention compared with an incarceration-to-community transitional intervention. We gathered information on any treatment-related adverse events. “Intermediate Outcomes,” which may lead to improved patient-centered outcomes, include adherence with treatment and mental health service access or use.

Figure 1 Analytic framework for interventions for adult offenders with serious mental illness

Note: KQ = Key Question.; SMI = serious mental illness

Figure 1. Analytic framework for interventions for adults with serious mental illness who are involved with the criminal justice system KQ=Key question; SMI=serious mental illness. Figure 1 depicts the population, treatment, and intermediate- and patient-oriented outcomes that are assessed in this report. On the far left side of the figure is a medium-sized box (Box 1) in which we describe the populations of interest: adults with SMI with and without a co-occurring alcohol or substance abuse diagnosis who are involved in one of the criminal justice system settings of interest. A right pointing arrow directs the reader to a larger box (Box 2) showing the criminal justice settings for Key Question 1 (KQ1) and Key Question 2 (KQ2). KQ1 compares interventions within an incarceration setting (jail, prison, or forensic hospital) or the same intervention applied across incarceration settings. KQ2 compares interventions provided during the transition from incarceration (jail, prison, or forensic hospital) to the community (e.g., family/home, halfway house). For KQ2, the comparisons are different interventions applied within an incarceration-to-community setting, the same intervention applied across settings, or an incarceration intervention compared with an incarceration-to-community transitional intervention. To the right is a smaller square box (Box 3) which lists the intermediate outcomes assessed in this report. “Intermediate outcomes,” which may lead to improved patient-oriented outcomes, include adherence with treatment and mental health service access or use. To the far right of the diagram in a large rectangular box (Box 4) we list the patient-oriented outcomes assessed: suicide and suicide attempts, quality of life, independent functioning, psychiatric symptoms, new mental health diagnosis, substance- or alcohol use, hospitalization for SMI, time to rehospitalization, time to relapse, dangerousness to others, and recidivism and other criminal justice outcomes. Underneath Box 2 is a downward pointing arrow which directs the reader to the fact that we gathered information on any treatment-related adverse events.

To the far right of the diagram we list the patient-oriented outcomes assessed: suicide and suicide attempts, quality of life, independent functioning, psychiatric symptoms, new mental health diagnosis, substance- or alcohol use, hospitalization for SMI, time to rehospitalization, time to relapse, dangerousness to others, and recidivism and other criminal justice outcomes.

### Populations

The population considered for this report is adults (18 years of age or older) with a diagnosis of schizophrenia, schizoaffective disorder, bipolar disorder, or major depression with or without a co-occurring substance abuse disorder who have been found guilty of a crime or not guilty by reason of insanity or its equivalent and who have been incarcerated for a minimum of 24 hours in one of the settings of interest. Diagnosis must have been made based on clinical assessment or a validated instrument administered by a professional. For this report, self-report alone did not qualify an individual as having an SMI.

### Interventions

The interventions considered in this report are listed in Table 1.

Table 1 Interventions by setting

Intervention^a^ | Jail | Prison | Forensic Hospital | Incarceration-to-Community Transitional Services^b^
Individual or group psychotherapy (e.g., cognitive behavior therapy or dialectical therapy) | X | X | X | X
Pharmacologic therapies (first-generation antipsychotics, second-generation antipsychotics, tricyclic antidepressants, monoamine oxidase inhibitors, selective serotonin-reuptake inhibitors, serotonin-norepinephrine reuptake inhibitors, mood stabilizers, anticonvulsants, and any other medications used in patients with SMI reported in the literature) | X | X | X | X
Specialized housing | X | X
Integrated dual disorder treatment (IDDT) | X | X | X | X
Telemedicine (telepsychiatry, telepsychology) | X | X | X | X
Discharge planning | X | X | X | X
Critical time interventions (CTI) | | | | X
Case management interventions | X | X | | X
Intensive community treatments (ACT or FACT) | | | | X
Modified therapeutic community (MTC) | | X | X | X
Other treatments (e.g., art therapy, music therapy, or peer support training) | X | X | X | X

a For the interventions, compelled versus voluntary treatment (e.g., forced medication vs. voluntary medication) was to be examined if the data permitted. However, there were no data available for this comparison.

b For the interventions, immediate access to mental health services upon release versus no or delayed access would be examined if data were available.

ACT = Assertive Community Treatment; FACT = Forensic Assertive Community Treatment

### Comparators

For KQ1, the comparators are usual care or any one of the interventions listed in Table 1 applied within in a jail, prison, or forensic hospital setting or the same intervention applied across settings.

For KQ2, the comparators are usual care or any one of the interventions listed in Table 1 applied within an incarceration-to-community transitional setting, the same intervention applied in different settings, or an incarceration intervention compared with an incarceration-to-community transitional intervention.

### Outcomes

Mental health outcomes:

- Completed suicide
- Suicide attempts
- Quality of life
- Independent functioning (including employment, housing, social integration)
- Psychiatric symptoms that characterize SMI
- New mental health diagnosis
- Substance or alcohol use
- Hospitalization for SMI
- Time to rehospitalization
- Time to relapse
- Dangerousness to others based on administrative records or validated assessment instruments
- Criminal justice outcomes in prison
- Infractions of prison code of conduct (time in administrative segregation, secure housing)
- Recidivism
- Reincarceration

Intermediate mental health outcomes:

- Mental health service access use
- Adherence with treatment

Adverse events including medication side effects

### Time Points

We required a minimum followup of 3 months for studies included in this report.

### Settings

- KQ1: jail, prison, and forensic hospital
- KQ2: jail-to-community, prison-to-community, and forensic hospital-to-community transitional services

## Organization of This Report

The remainder of this review describes our methods and results in detail and provides a discussion of our findings and recommendations for future research. Appendixes provide details of the literature search methods (Appendix A); forms used for title, abstract, and full article review (Appendix B); studies excluded at the full-text review stage (Appendix C); risk-of-bias assessments for studies included in this report (Appendix D); general study, treatment, and patient characteristics of included trials (Appendix E); and comprehensive evidence tables (Appendix F); as well as relevant guidelines (Appendix G); previous systematic reviews (Appendix H); and ongoing clinical trials (Appendix I).