# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- J. Steven Lamberti, M.D.
  Professor, Department of Psychiatry
  University of Rochester Medical Center
  Rochester, NY
- Joseph Morrissey, Ph.D.
  Professor of Health Policy and Management
  Gillings School of Global Public Health, University of North Carolina
  Chapel Hill, NC
- Phyllis Solomon, Ph.D.
  Professor, School of Social Policy & Practice
  University of Pennsylvania
  Philadelphia, PA