# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Paul Appelbaum, M.D.
  Director, Division of Psychiatry, Law, and Ethics
  Columbia University Medical Center
  New York, NY
- William Fisher, Ph.D.
  Professor, Center for Mental Health Services Research
  University of Massachusetts Medical School
  Amherst, MA
- Denise Juliano-Bult, M.S.W.
  Program Chief, Division of Services and Intervention Research
  National Institute of Mental Health
  Bethesda, MD
- Jeffrey L. Metzner, M.D.
  Clinical Professor of Psychiatry
  University of Colorado School of Medicine
  Denver, CO
- Joseph Penn, M.D., C.C.H.P.
  Director, Medical Health Services
  University of Texas Medical Branch
  Correctional Managed Care for the Texas
  State Prison System
  Huntsville, TX
- Marc F. Stern, M.D., M.P.H.
  Assistant Affiliate Professor, School of Public Health
  University of Washington
  Olympia, WA
- Amy Blank Wilson, Ph.D.
  Assistant Professor, Mandel School of Applied Social Sciences
  Case Western Reserve University
  Cleveland, OH
- David B. Wilson, Ph.D.
  Professor and Chair
  Department of Criminology, Law and Society
  George Mason University
  Fairfax, VA
- Nancy Wolff, Ph.D.
  Professor and Director, Center for Behavioral Health Services & Criminal Justice Research
  Rutgers, the State University of New Jersey
  New Brunswick, NJ