# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Kenneth Duckworth, M.D.
  Medical Director
  National Alliance for the Mentally Ill
  Arlington, VA
- Catherine Gallagher, Ph.D.
  Director, Cochrane Collaboration Policy College
  George Mason University
  Fairfax, VA
- Doris Lotz, M.D., M.P.H.
  New Hampshire Medicaid Medical Director
  State of New Hampshire Department of Health and Human Services
  Concord, NH
- Joseph Penn, M.D., C.C.H.P.
  Director, Medical Health Services
  University of Texas Medical Branch
  Correctional Managed Care for the Texas
  State Prison System
  Huntsville, TX
- Janet Warren, D.S.W.
  Professor, Department of Psychiatry and Neurobehavioral Sciences
  University of Virginia
  Charlottesville, VA