# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Pam Lattimore, Ph.D., of RTI International–University of North Carolina at Chapel Hill for providing background on how this topic was identified as a research area requiring a comparative effectiveness review; our AHRQ Task Order Officer, Kim Wittenberg, M.A.; and our EPC Associate Editor, Kathleen Lohr, Ph.D. We extend our appreciation to our Key Informants for providing guidance on Key Question development and members of the Technical Expert Panel (listed below), who assisted in the protocol development process. We are grateful for their valuable contribution to this report. The EPC would also like to thank Michelle Datko, M.S.L.I.S., and Helen Dunn for providing literature retrieval and documentation management support; Lydia Dharia for her assistance with the final preparation of the report; and Gina Giradi, M.S., for her oversight and coordination of all project-related activities.