# Discussion

## Key Findings and Strength of Evidence

This review covered the treatment of offenders with serious mental illness (SMI). This is a population that has trouble coping with prison life and is more likely to return to incarceration following release than offenders without SMI.

Two studies (low strength of evidence) suggest that providing incarcerated inmates with antipsychotics other than clozapine may improve psychiatric symptoms better than treatment with clozapine.68,69

Two studies (low strength of evidence) suggest that providing inmates with discharge planning that includes Medicaid application assistance is likely to increase their use of mental health services upon release.78,79 Theoretically, increasing individuals’ use of mental health service will lead to better control of their mental health symptoms, which, in turn, may lessen future contacts with the criminal justice system.

The findings of this review also suggest that providing offenders who have dual diagnoses with a comprehensive, integrated dual disorder treatment (IDDT) intervention increases mental health service use both during and after release from incarceration and may reduce psychiatric hospitalizations better than standard of care (low strength of evidence).78,81,82 See Table 19 below for more detail.

Table 19 Summary of findings for Key Question 1 and Key Question 2

Key Question | Comparison | Outcome | SOE Grade
Key Question 1 – incarceration setting | Clozapine vs. other antipsychotics | Psychiatric symptoms | Low in favor of antipsychotics other than clozapine
Key Question 1 – incarceration setting | Clozapine vs. other antipsychotics | Independent functioning | Insufficient
Key Question 1 – incarceration setting | Risperidone vs. other antipsychotics | Psychiatric symptoms; institutional infractions | Insufficient
Key Question 1 – incarceration setting | High dose chlorpromazine vs. standard dose | Psychiatric symptoms | Insufficient
Key Question 1 – incarceration setting | Cognitive problem solving group (R&R) vs. treatment as usual | Psychiatric symptoms | Insufficient
Key Question 1 – incarceration setting | Cognitive group therapy vs. individual supportive therapy | Psychiatric symptoms | Insufficient
Key Question 1 – incarceration setting | Modified therapeutic community vs. intensive outpatient | Psychiatric symptoms; substance abuse; criminal justice outcomes | Insufficient
Key Question 1 – incarceration setting | Modified therapeutic community vs. standard mental health treatment | Psychiatric symptoms; substance abuse; criminal justice outcomes | Insufficient
Key Question 2 – incarceration-to-community transition setting | Discharge planning with benefit-application assistance vs. no application assistance | Mental health service use upon release^a^ | Low in favor of discharge planning with benefit-application assistance
Key Question 2 – incarceration-to-community transition setting | Intensive jail treatment followed by high-fidelity IDDT vs. intensive jail treatment followed by treatment as usual | Psychiatric symptoms (crisis visits) | Insufficient
Key Question 2 – incarceration-to-community transition setting | IDDT vs. treatment as usual in the community | Psychiatric hospitalization (administrative records) | Low in favor of IDDT
Key Question 2 – incarceration-to-community transition setting | Mentally ill chemical abuser treatment vs. treatment as usual | Function (correctional facility agent reports) | Insufficient
Key Question 2 – incarceration-to-community transition setting | Mentally ill chemical abuser treatment vs. treatment as usual | Medication adherence (correctional facility agent reports) | Insufficient
Key Question 2 – incarceration-to-community transition setting | Mentally ill chemical abuser treatment vs. treatment as usual | Substance use (urinalysis) | Insufficient
Key Question 2 – incarceration-to-community transition setting | IDDT vs. treatment as usual in the community | Mental health service use upon release (administrative records)^a^ | Low in favor of IDDT
Key Question 2 – incarceration-to-community transition setting | IDDT vs. treatment as usual | Mental health service use during incarceration (administrative records)^a^ | Low in favor of IDDT
Key Question 2 – incarceration-to-community transition setting | Mentally ill chemical abuser vs. treatment as usual | Institutional infractions (time in segregation; conduct reports) | Insufficient
Key Question 2 – incarceration-to-community transition setting | Interpersonal therapy vs. psychoeducation | Psychiatric symptoms (HRSD); substance abuse (urinalysis) | Insufficient

a Intermediate outcome

HRSD = Hamilton Rating Scale for Depression; IDDT = integrated dual diagnosis treatment; R&R = Reasoning and Rehabilitation; SOE = strength of evidence

## Findings in Relationship to What Is Already Known

### Key Question 1

Our searches found 10 previous systematic reviews on treatments assessed under Key Question 1 or interventions relevant to this review. (See Table H1 in Appendix H.) Two comprehensive systematic reviews have been conducted on interventions for offenders with SMI; however, neither review described the interventions assessed in their included studies and both conducted meta-analyses based on single treatment components (e.g., presence or absence of a homework component).20,21 An important goal of our review is to describe incarceration-based and incarceration-to-community interventions in a manner that will allow treatment providers to replicate effective treatments and to identify gaps in the scientific literature for future research in the field.

Two of the previous systematic reviews examined the effectiveness of pharmacologic therapy for treating offenders who have mental illness. Griffiths and colleagues found that using more than one psychotropic medication simultaneously was a common practice in prison, as was prescribing medication at doses above the recommended maximum daily amount.22 Huband and colleagues examined the effectiveness of antiepileptic pharmacologic therapy on prisoners with personality disorders and a variety of other individuals requiring treatment for recurrent aggression. These researchers identified one study demonstrating that high-dose diphenylhydantoin was superior to low-dose diphenylhydantoin in reducing the intensity and frequency of aggressive outbursts.23

In our review, one study assessed high-dose versus standard-dose pharmacotherapy (chlorpromazine).70 Investigators found more side effects among patients on the higher dose.

Another previous systematic review, by Nagi and Davies, examined the effectiveness of psychological interventions on reoffending behavior in a variety of male offender populations.24 The authors performed a qualitative synthesis of the evidence and concluded that cognitive behavior therapy was the most effective treatment and the most commonly offered treatment in low-security forensic settings.24

Our review did not find cognitive therapy to be more effective than standard psychological treatment, but differences in trials’ inclusion and exclusion criteria, including the exclusion in the Nagi and Davies review of trials conducted on female prisoners, may explain the difference in our results.

Another earlier systematic review examined the effectiveness of modified therapeutic community (MTC) compared with the effectiveness of standard of care. However, this review, by S. Sacks and colleagues, included only studies conducted by the author’s own research team. They reported that, based on a qualitative synthesis, MTC was superior to standard of care in improving both mental health and criminal justice outcomes.25 We thought that the heterogeneity of the study populations and interventions was too great in these studies for us to feel comfortable combining them in a meta-analysis.

### Key Question 2

For Key Question 2, the incarceration-to-community transitional setting, limited evidence exists showing that discharge planning with benefit-application assistance increased subjects’ use of mental health services upon release from incarceration.78,79 Limited evidence also exists showing that IDDTs were more effective than standard treatments in reducing psychiatric hospitalizations and increasing mental health service use both during and upon release from incarceration.78,81,82 One qualitative research synthesis examined the effectiveness of community-based interventions, including assertive community treatment (ACT), intensive case management, and other reentry initiatives compared with the effectiveness of treatment as usual upon release from incarceration.86 On the whole, offenders with SMI did better if they received ACT, intensive case management, or other correctional reentry interventions than those receiving treatment as usual upon release.

Two studies assessed the efficacy of treatments provided by forensic specialists versus mental health generalists. However, because these two trials reported different outcomes of interest, we judged the evidence insufficient to draw a conclusion.83,87 More research is needed to better assess the impact of provider type on treatment outcomes. However, one ongoing trial is testing the efficacy of forensic assertive community treatment (FACT) with enhanced outpatient treatment for individuals with a psychotic disorder who are facing criminal charges but who have not yet been sentenced. This trial is due to be completed in May 2014. Once the findings of this trial are published, we may be able to draw a conclusion about the effectiveness of forensic specialist–provided treatments.

## Implications for Clinical and Policy Decisionmaking

Our conclusions that a limited number of interventions improve outcomes among offenders with SMI were based on evidence of low strength. Mental health care providers and correctional facility administrators need to consider whether to implement these treatments based on limited evidence of their effectiveness or wait until more evidence becomes available about their comparative effectiveness. This report did not gather information on the costs associated with implementing these treatments or the potential societal costs of not implementing them.

Three recent, relevant guidelines were also identified in our literature searches. In the incarceration setting, one guideline each addressed pharmacological therapy for offenders with schizophrenia and major depressive disorder. The National Commission on Correctional Health Care and Applied Clinical Education, 2009, recommends that drug selection for incarcerated schizophrenics should mirror drug selection for nonoffending schizophrenics living in the community.26 The Federal Bureau of Prisons, 2009, recommends pharmacotherapy as first-line treatment for patients with major depressive disorder, with electroconvulsive therapy for severe and urgent situations. Psychotherapy should be an adjunctive treatment in this population.27 The third guideline focused on improving mental health in offenders with SMI living in community correctional settings. Six interventions were identified as being likely to benefit this population: ACT, Self-management and Recovery, integrated dual diagnosis services, supported employment, psychopharmacology, and family psychoeducation.28

## Limitations of the Evidence Base

The main limitation of this evidence base was the paucity of comparative trials assessing interventions for offenders with SMI in an incarceration or incarceration-to-community transitional setting. Only a handful of interventions were identified for each of the two Key Questions addressed by this report, although we know from our searches that other treatments, such as telepsychiatry and telepsychology, are gaining popularity in these settings. Other limitations include the following:

- Few female offenders or offenders with bipolar disorder or major depression were addressed in the trials that made up our evidence base.
- None of the treatments evaluated for KQ1, the incarceration setting, took place in jail, which houses inmates who have committed less serious offenses for shorter stays.
- Variability exists in how researchers define SMI. For instance, according to State Mental Health Parity laws, only Diagnostic and Statistical Manual of Mental Disorders, fourth edition, text revision Axis I diagnoses characterized by psychosis or an affective element (e.g., schizophrenia, major depressive disorder) are considered to be an SMI. Other, more clinically-based definitions emphasize a combination of diagnosis, duration of illness, and degree of functional disability.88,89
- Treatment fidelity was noted to be poor in most of the trials that reported this parameter.
- The authors did not describe the comparator treatment in many of the trials in as much detail as the treatment of interest, making it difficult to assess whether the comparator tested was the best comparator available.
- Attrition was quite high in some of the studies.
- For KQ2, in particular, patient-oriented outcome reporting was lacking.

Therefore, for most outcomes, we graded the strength of evidence as insufficient for both the incarceration and incarceration-to-community transitional settings.

For KQ1 specifically, all of the included trials had a medium risk of bias and reported patient-oriented (or direct) outcomes. The main problem with the evidence base was the limited number of trials assessing the same intervention and same or comparable outcomes. Therefore, we graded the strength of evidence for KQ1 as insufficient for most outcomes.

For KQ2, all but one of the included trials had a medium risk of bias; but, again, there were simply too few studies assessing the same intervention. For instance, the largest evidence base (3 trials) assessed IDDT, but because only two of the three trials reported the same outcome, we assessed the strength of evidence as low.

Many restrictions are placed on investigators interested in conducting research in the incarceration and incarceration-to-community settings, which may explain why so few studies were identified and included in this review. In 2006, the Committee on Ethical Considerations for Revisions to DHHS [U.S. Department of Health and Human Services] Regulations for Protection of Prisoners Involved in Research published a report aimed at increasing the protection of prisoners involved in research trials. The committee made several recommendations that make conducting clinical research more challenging in this setting. Specifically, some of the committee recommendations included the provision that investigators collaborate with prisoners and correction officers on the design and conduct of the research. To ensure that prisoners are not participating in research solely to gain access to adequate health care, all prisoners should have access to adequate health care even if they choose not to participate in a clinical trial. To protect research subjects, confidentiality is supposed to be maintained and a prison research subject advocate should be employed at the research site to oversee all research activities.90

## Limitations of the Comparative Effectiveness Review Process

This report considered treatments for offenders with SMI. Some trials were eliminated from inclusion because we were unable to determine whether the study population had SMI or because investigators relied on self-reported mental illness as the basis for enrolling patients into the trial.

We also limited our evidence base to studies that reported at least one mental health outcome. A handful of studies identified in our literature search were excluded for failing to report a mental health outcome.

Another difficulty encountered in conducting this review was the tendency of study authors to describe the intervention of interest in detail while poorly describing the treatment comparator. This was particularly pronounced when the comparator was treatment as usual. Some of the included trials also reported more outcomes for the treatment of interest than for the comparator treatment. In some instances, it seems that the authors had more information about participants who received the treatment of interest. This may have been due to our inclusion of retrospectively conducted comparative trials.

Finally, noncomparative trials were the more common study design identified in our literature searches, but because this is a comparative effectiveness review we were unable to use data from those reports. As previously stated, more comparative trials are needed on this topic.

## Research Gaps

### Methodological Considerations

Much of the research in this field uses a case series design, assessing the same patients before and after treatment. Unfortunately, because most mental illness symptoms tend to wax and wane over time, this is not the preferred study design for this particular population. Few comparative trials were available that assessed treatments for offenders with SMI.

Some comparative trials compared results in subjects receiving one active treatment with results of subjects not receiving any treatment. Treatment comparators should be the best comparator available, which may be the standard of care. Because the standard of care may vary from one setting to another, a good description of the treatment provided is important.

Treatment fidelity was not consistently reported by study authors, and when it was reported, it was often found to be inadequate. Going forward, researchers may attempt to closely monitor and maintain fidelity throughout the trial, so the treatments’ maximum benefit potentials can be determined. Once a program is established, researchers can attempt to implement it with some variations to see if the treatment effect remains constant.

As expected with vulnerable populations, attrition was high in some of the included trials. In one trial, 1-year followup data could not be assessed because more than 50 percent of the sample had dropped out by that point. Intention-to-treat analysis could be employed to help overcome this shortcoming.

### Substantive Gaps

Overall, we found few trials with active comparators that assessed the impact on mental health of treatments for offenders with SMIs. Below we outline specific research gaps based on the PICOS (population, intervention, comparator, outcome, and setting) framework.

#### Female and Mood-Disordered Incarcerated Research Participants

For treatments administered in the incarceration setting, all but one of the included trials enrolled male offenders. One study of MTC was the exception. We also found that most of the included trials, including all of the pharmacologic therapy trials, enrolled patients with schizophrenia or schizoaffective disorder or both. The all-female MTC intervention was one of only two trials to enroll offenders with bipolar disorder.

Offenders with depression were underrepresented in the included studies for KQ1. Approximately 60 percent of the all-female MTC intervention had a diagnosis of depression and 100 percent of those in the study assessing group cognitive therapy were depressed. Although we recognize that the jail and prison populations are predominantly male, researchers should consider studying the effectiveness of pharmacotherapy, cognitive therapy, and MTC interventions in female offenders and in those with primary mood disorders.

#### Comparative Trials of Other Commonly Used Interventions

Comparative studies of other commonly used interventions would be useful for decisionmaking. For example, one systematic review by Khalifa and colleagues reported that videoconferencing appears to be an effective treatment in incarceration settings, but that review included noncomparative trials.29

For treatments administered in the incarceration-to-community setting, we noted that the studies were fairly representative of offenders regardless of their sex, ethnicity, or SMI diagnosis. However, very few treatments were studied in the incarceration-to-community setting. For example, no trials of medication initiated in incarceration and continued in the community were identified.

#### Balanced Reporting of All Interventions Assessed

The included trials addressing KQ1 tended to describe the treatment of interest in detail but provided very little information about the comparator treatment. In one of the clozapine trials, the study author did not provide details beyond that clozapine was being compared to other antipsychotics. Neither of the clozapine trials reported the dosage of the antipsychotic comparator(s). More detailed information about comparators is needed, so researchers can replicate existing studies and to ensure that studies are using the best comparator available.

As with KQ1, the included trials that addressed KQ2 tended to describe the treatment of interest in detail but provided very little information about the comparator treatment, the education level of its provider, and whether ancillary treatments were also received by study participants. Balanced descriptions of both trial arms would make future research reports more informative.

#### Standardization of Assessment Tools

Future research could also standardize which outcomes are reported and how these outcomes are measured. For instance, investigators used different assessment tools for measuring the same outcome and focused on different underlying constructs (Maudsley Violence Questionnaire and Social Problem Solving Inventory) for the same outcome. We were unable to perform meta-analysis of Reasoning and Rehabilitation in an incarceration setting because of this variability in measuring psychiatric symptoms. More standardization, including the use of validated assessment instruments, is needed.

#### Comparative Trials in the Jail Setting

None of the trials that addressed KQ1 was conducted in a jail setting. More research is needed on the effectiveness of pharmacotherapy, cognitive therapy, and MTC for offenders with SMI who experience longer stays (several months) in a jail setting. It is not clear whether the findings from other settings (e.g., prison) would also apply to longer-stay jail inmates. All settings of interest were represented among the trials that addressed KQ2.

#### Patient-Oriented Outcome Reporting

Future researchers might also consider reporting more downstream, patient-oriented outcomes. Some of our main findings for KQ2 relate to treatments that improve mental health service use. However, based on the available evidence, we cannot determine if increased service use led to improved patient outcomes such as a decrease in psychiatric symptoms.

#### Attrition

In the future, researchers might also consider offering research participants incentives to decrease attrition rates. Attrition rates greater than 50 percent occurred in some of the included trials.

#### Ongoing Clinical Trials

We identified six ongoing comparative trials—five randomized controlled trials and one retrospective comparison—through the National Clinical Trials database, ClinicalTrials.gov, and the NIH Reporter. Two trials each are sponsored by the National Institute of Mental Health and academic institutions, and one trial each is sponsored by industry and the National Institute on Drug Abuse. The trials are testing the following interventions:

- Critical time interventions versus enhanced reentry services for men with mental illness leaving prison
- The Massachusetts Department of Mental Health Forensic Transition Team versus treatment as usual for offenders with SMI
- FACT versus enhanced outpatient followup without judicial monitoring in psychotic offenders
- Interpersonal therapy (IPT) plus treatment as usual versus treatment as usual for male and female offenders with major depressive disorder
- Monthly paliperidone palmitate injection versus oral antipsychotic treatments in delaying time to treatment failure for incarcerated individuals with schizophrenia
- MTC versus standard case management and parole supervision for prisoners with dual diagnoses.

The trials were expected to be completed between July 2011 and October 2014. Their expected enrollment ranges from 53 to 442 subjects. Once published, the additional evidence may allow a more robust conclusion in systematic reviews. See Table I-1 in Appendix I for more detail on the ongoing trials.

## Conclusions

We identified few comparative trials assessing interventions for offenders with SMI in an incarceration or incarceration-to-community setting. We graded the strength of the body of available evidence as low to insufficient for both the incarceration and incarceration-to-community settings. Results are presented below for interventions that were tested in a minimum of two trials that reported the same outcome.

For treatment in the incarceration setting, antipsychotics other than clozapine improved psychiatric symptoms better than clozapine. Clozapine was associated with a high rate of adverse events. Cognitive therapy was compared with other psychological treatment in three trials. Two trials found clients treated with cognitive therapy improved more than clients treated with standard psychological treatment on some but not all outcome measures; the third trial did not find a difference by treatment group.

Two trials that evaluated MTC versus standard treatment, one in female offenders and the other in a male population, found no between-group differences in psychiatric symptoms. Both trials reported substance abuse, with one favoring MTC and the other finding no difference by treatment arm. These trials also assessed several measures of recidivism but had conflicting results, with one favoring MTC and the other trial finding no difference between MTC and standard treatment.

For the incarceration-to-community setting, two trials assessed discharge planning with benefit-application assistance, three trials assessed IDDT, and two trials assessed forensic specialist services. Both trials that specified study participants received assistance with their benefit applications as part of the discharge planning process, whether alone or in combination with other interventions, found this to be an effective treatment for increasing service use. However, discharge planning was combined with additional treatment components, so it is unclear what role those additional components may have had on service use upon release from incarceration.

Two studies clearly fell into the IDDT category, and we classified a third study, by Theurer and Lovell, in that category as well, given its high rate of study participants with dual diagnoses and the fact that substance abuse counseling was one component in the comprehensive Mentally Ill Offender Community Transition Program (MIOCTP) these authors evaluated. Two dual-diagnoses trials reported that psychiatric hospitalizations were reduced and that service use, both during incarceration and upon release, was increased among clients who received IDDT compared with these outcomes in other, nondual-diagnoses treatments.

One trial compared treatment provided by a forensic specialist with treatment as usual and with ACT. A second trial compared treatment by a forensic specialist with treatment provided by a mental health generalist. Insufficient evidence existed to draw a conclusion about the comparative effectiveness of treatments administered by a forensic specialist over a mental health generalist for psychiatric symptomology, psychiatric hospitalization, substance abuse, quality of life, and completed suicide because only one trial reported these outcomes.

In sum, correctional facilities may want to consider using antipsychotics other than clozapine for incarcerated offenders and adding discharge planning with benefit-application assistance and IDDT to the treatments they currently provide to offenders with SMIs reentering the community.

The next logical step for experts in the field is to conduct more research targeted at the interventions and populations for which evidence is lacking.