# Ongoing Clinical Trials

Table I1 Ongoing clinical trials