# Previous Systematic Reviews

Table H1 Previous systematic reviews