# Guidelines

Table G1 Relevant guidelines