# Evidence Tables for Key Questions 1 and 2

## Key Question 1

Table F1 Key Question 1: psychiatric symptoms

Table F2 Key Question 1: improvement status

Table F3 Key Question 1: independent functioning

Table F4 Key Question 1: institutional infractions

Table F5 Key Question 1: mental health and substance abuse service use

Table F6 Key Question 1: substance use

Table F7 Key Question 1: criminal justice outcomes

Table F8 Key Question 1: time to reincarceration or recidivism

Table F9 Key Question 1: adverse events

## Key Question 2

Table F10 Key Question 2: increase in psychiatric symptoms

Table F11 Key Question 2: psychiatric hospitalization

Table F12 Key Question 2: level of function

Table F13 Key Question 2: medication adherence

Table F14 Key Question 2: substance use

Table F15 Key Question 2: quality of life

Table F16 Key Question 2: completed suicide

Table F17 Key Question 2: service use during incarceration

Table F18 Key Question 2: institutional infractions

Table F19 Key Question 2: criminal justice outcomes

Table F20 Key Question 2: mental health service use upon release