# Study, Treatment, and Patient Characteristics for Key Questions 1 and 2

## Key Question 1

Table E1 Key Question 1: general study characteristics

Table E2 Key Question 1: treatment characteristics

Table E3 Key Question 1: additional treatment characteristics

Table E4 Key Question 1: participant characteristics

Table E5 Key Question 1: additional participant characteristics

## Key Question 2

Table E6 Key Question 2: general study characteristics

Table E7 Key Question 2: treatment characteristics

Table E8 Key Question 2: additional treatment characteristics

Table E9 Key Question 2: participant characteristics

Table E10 Key Question 2: additional participant characteristics