# Risk-of-Bias Assessment for Key Questions 1 and 2

Table D1 Risk-of-bias assessment for Key Question 1

Outcome | Study | Q1. Were pts. randomly assigned to study groups? | Q2. Was the process of assigning patients to groups made independently from physician/mental health care provider and patient preference? | Q3 For nonrandomized trials, did the study employ any other methods to enhance group comparability? | Q4. Was comparison of interest prospectively planned? | Q5. Were all study groups concurrently treated? | Q6 Were those who assessed the patients’ outcomes blinded to the group to which the patients were assigned? | Q7 Was the outcome measure of interest objective and was it objectively measured? | Q8 Was the treatment applied consistently across study subjects and over time? | Q9. Was there a ≤5 difference between groups in ancillary treatment(s)? | Q10 Was there ≤15% difference in the length of followup for the two groups? | Q11 Did ≥85% of enrolled patients provide data at the time point of interest? | Q12 Was there a ≤15% difference between groups in the percentage of patients who provided data at the time point of interest? | Q13 Was funding free of financial interest? | Overall Risk of Bias Category
Psychiatric Symptoms | Rees-Jones et al., 2012^66^ | No | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | No | Yes | NR | medium
Psychiatric Symptoms | Cullen et al., 2011^67^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | No | Yes | medium
Psychiatric Symptoms | Balbuena et al., 2010^68^ | No | No | Yes | No | Yes | No | No | Yes | NR | Yes | Yes | Yes | Yes | medium
Psychiatric Symptoms | Martin et al., 2008^69^ | No | No | Yes | No | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | medium
Psychiatric Symptoms | J. Sacks et al., 2008^64,65^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | No | Yes | No | Yes | NR | medium
Psychiatric Symptoms | Sullivan et al., 2007^631^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | NR | Yes | No | Yes | NR | medium
Psychiatric Symptoms | Tavernor et al., 2000^70^ | No | No | Yes | Yes | Yes | NR | No | Yes | Yes | Yes | Yes | Yes | Yes | medium
Psychiatric Symptoms | Beck et al., 1997^71^ | No | NR | Yes | Yes | No | NR | No | Yes | Yes | Yes | Yes | Yes | NR | medium
Psychiatric Symptoms | Wilson, 1990^72^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | NR | Yes | Yes | Yes | Yes | medium
Substance Use/Abuse | J. Sacks et al., 2008^64,65^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | No | Yes | No | Yes | NR | medium
Substance Use/Abuse | Sullivan et al., 2007^62^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | NR | Yes | No | Yes | NR | medium
Infractions | Balbuena et al., 2010^68^ | No | No | Yes | Yes | Yes | No | Yes | Yes | NR | Yes | Yes | Yes | Yes | medium
Dangerousness/Aggression Toward Others | Beck et al., 1997^71^ | No | NR | Yes | Yes | No | NR | No | Yes | Yes | Yes | Yes | Yes | NR | medium
Recidivism or Re-incarceration | S. Sacks et al., 2004^61^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | NR | Yes | No | No | Yes | Medium
Other Criminal Activity (e.g., self-reported criminal behavior) | J. Sacks et al., 2008^64,65^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | No | Yes | No | Yes | NR | medium
Other Criminal Activity (e.g., self-reported criminal behavior) | S. Sacks et al., 2004^61^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | NR | Yes | No | No | Yes | Medium

Table D2 Risk-of-bias assessment Key Question 2

Outcome | Study | Q1. Were pts. randomly assigned to study groups? | Q2. Was the process of assigning patients to groups made independently from physician/mental health care provider and patient preference? | Q3 For nonrandomized trials, did the study employ any other methods to enhance group comparability? | Q4. Was comparison of interest prospectively planned? | Q5. Were all study groups concurrently treated? | Q6 Were those who assessed the patients’ outcomes blinded to the group to which the patients were assigned? | Q7 Was the outcome measure of interest objective and was it objectively measured? | Q8 Was the treatment applied consistently across study subjects and over time? | Q9. Was there a ≤5 difference between groups in ancillary treatment(s)? | Q10 Was there ≤15% difference in the length of followup for the two groups? | Q11 Did ≥85% of enrolled patients provide data at the time point of interest? | Q12 Was there a ≤15% difference between groups in the percentage of patients who provided data at the time point of interest? | Q13 Was funding free of financial interest? | Overall Quality Category
Psychiatric Symptoms | Johnson and Zlotnick, 2012^35^ | Yes | Yes | Yes | Yes | No | Yes | No | Yes | No | Yes | Yes | Yes | Yes | low
Psychiatric Symptoms | Chandler and Spicer, 2006^81^ | Yes | Yes | Yes | Yes | Yes | NR | No | Yes | Yes | Yes | No | NR | Yes | medium
Psychiatric Symptoms | Solomon and Draine, 1995^83^ | Yes | Yes | Yes | Yes | Yes | NR | No | No | No | Yes | No | No | Yes | medium
Psychiatric Hospitalization | Coid et al., 2007^80^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | Yes | Yes | No | medium
Psychiatric Hospitalization | Chandler and Spicer, 2006^81^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | No | NR | Yes | medium
Psychiatric Hospitalization | Van Stelle and Moberg, 2004^82^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | No | No | Yes | medium
Substance Use/Abuse | Johnson and Zlotnick, 2012^35^ | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | low
Substance Use/Abuse | Van Stelle and Moberg, 2004^82^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | No | No | Yes | medium
Substance Use/Abuse | Solomon and Draine, 1995^83^ | Yes | Yes | Yes | Yes | Yes | NR | No | No | No | Yes | No | No | Yes | medium
Quality of Life | Solomon and Draine, 1995^83^ | Yes | Yes | Yes | Yes | Yes | NR | No | No | No | Yes | No | No | Yes | medium
Completed Suicide | Coid et al., 2007^80^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | Yes | Yes | No | Medium
Service Use | Chandler and Spicer, 2006^81^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | No | NR | Yes | medium
Service Use | Van Stelle and Moberg, 2004^82^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | No | No | Yes | medium
Service Use | Theurer and Lovell, 2008^78^ | No | Yes | Yes | No | No | No | Yes | No | No | Yes | Yes | Yes | Yes | medium
Service Use | Wenzlow et al., 2011^79^ | No | Yes | Yes | No | Yes | NR | Yes | No | No | Yes | Yes | Yes | Yes | medium
Service Use | Solomon and Draine, 1995^83^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | No | No | Yes | No | No | Yes | medium
Infractions | Van Stelle and Moberg, 2004^82^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | No | No | Yes | medium
Recidivism or Re-incarceration | Chandler and Spicer, 2006^81^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | No | NR | Yes | medium
Recidivism or Re-incarceration | Solomon and Draine. 1995^83^ | Yes | Yes | Yes | Yes | Yes | NR | Yes | No | No | Yes | No | No | Yes | medium
Recidivism or Re-incarceration | Van Stelle and Moberg, 2004^82^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | No | No | Yes | medium
Recidivism or Re-incarceration | Coid et al., 2007^80^ | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | Yes | Yes | Yes | No | medium
Recidivism or Re-incarceration | Theurer and Lovell, 2008^78^ | No | Yes | Yes | No | No | No | Yes | No | No | Yes | Yes | Yes | Yes | medium

NR=Not reported; pts.=patients