# Full-length Review Excluded Studies

## Not a Comparative Trial With Independent Control Group of Interest

Prevention of jail and hospital recidivism among persons with severe mental illness. Psychiatr Serv. Nov. 1999;50(11):1477-80. [pmid: 10543867].
A model prison diversion program. Psychiatr Serv. Nov. 2000;51(11):1440-2. [pmid: 11203237].
Alcock D, White T. Study of the clinical and forensic outcome of admission to a forensic psychiatry day hospital at one, two, and three years. J Forensic Psychiatry Psychol. 2009;20(1):107-119.
Arnold EM, Stewart JC, McNeece CA. Enhancing services for offenders: the impact on treatment completion. J Psychoactive Drugs. Jul–Sep. 2001;33(3):255-62. [pmid: 11718318].
Baillargeon J, Black SA, Contreras S, et al. Anti-depressant prescribing patterns for prison inmates with depressive disorders. J Affect Disord. Mar. 2001;63(1–3):225-31. [pmid: 11246100].
Baillargeon J, Penn JV, Knight K, et al. Risk of reincarceration among prisoners with co-occurring severe mental illness and substance use disorders. Admin Policy Ment Health. Jul. 2010;37(4):367-74.
Bartels SJ, Teague GB, Drake RE, et al. Substance abuse in schizophrenia: service utilization and costs. J Nerv Ment Dis. Apr. 1993;181(4):227-32. [pmid: 8473874].
Boothroyd RA, Poythress NG, McGaha A, et al. The Broward Mental Health Court: process, outcomes, and service utilization. Int J Law Psychiatry. Jan–Feb. 2003;26(1):55-71. [pmid: 12554000].
Citrome L, Volavka J. Pharmacological management of acute and persistent aggression in forensic psychiatry settings. CNS Drugs. 2011;25(12):1009-1021. [pmid: 22133324].
Constantine R, Andel R, Petrila J, et al. Characteristics and experiences of adults with a serious mental illness who were involved in the criminal justice system. Psychiatr Serv. May. 2010;61(5):451-57. [pmid: 20439364].
Cusack KJ, Steadman HJ, Herring AH. Perceived coercion among jail diversion participants in a multisite study. Psychiatr Serv. Sep. 2010;61(9):911-6. [pmid: 20810590].
Daniel C, Jackson J, Watkins J. Utility of an intensive behavior therapy unit in a maximum security female prison. Behav Ther. Jan. 2003;26(1):211-2.
Draine J, Solomon P. Jail recidivism and the intensity of case management services among homeless persons with mental illness leaving jail. J Psychiatr Law. 1994;22(2):245-61.
Draine J, Solomon P. Threats of incarceration in a psychiatric probation and parole service. Am J Orthopsychiatry. Apr. 2001;71(2):262-7. [pmid: 11347368].
Drapalski AL, Youman K, Stuewig J, et al. Gender differences in jail inmates’ symptoms of mental illness, treatment history and treatment seeking. Crim Behav Ment Health. 2009;19(3):193-206. [pmid: 19533597].
Dvoskin JA, Steadman HJ. “Using intensive case management to reduce violence by mentally ill persons in the community”: Correction”. Hosp Community Psychiatry. Oct. 1994;45(10):1004.
Feldman HS. Loxapine succinate as initial treatment of hostile and aggressive schizophrenic criminal offenders. J Clin Pharmacol. Aug–Sep. 1982;22(8–9):366-70. [pmid: 7130427].
Felthous AR, Weaver D, Evans R, et al. Assessment of impulsive aggression in patients with severe mental disorders and demonstrated violence: inter-rater reliability of rating instrument. J Forensic Sci. Nov. 2009;54(6):1470-1474. [pmid: 19818113].
Foley TR, Goldenberg EE, Bartley F, et al. The development of a clozapine treatment program for offenders in a correctional mental health prison. Int J Offender Ther Comp Criminol. 1995;39:353-58.
Friedmann PD, Melnick G, Jiang L, et al. Violent and disruptive behavior among drug-involved prisoners: Relationship with psychiatric symptoms. Behav Sci Law. 2008;26(4):389-401. [pmid: 18683200].
Geelan SD, Campbell MJ, Bartlett A. What happens afterwards? A follow-up study of those diverted from custody to hospital in the first 2.5 years of a metropolitan diversion scheme. Med Sci Law. Apr. 2001;41(2):122-8. [pmid: 11368392].
Gilbert AR, Moser LL, Van Dorn RA, et al. Reductions in arrest under assisted outpatient treatment in New York. Psychiatr Serv. Oct. 2010;61(10):996-9. [pmid: 20889637].
Godley SH, Finch M, Dougan L, et al. Case management for dually diagnosed individuals involved in the criminal justice system. J Subst Abuse Treat. Mar. 2000;18(2):137-48. [pmid: 10716097].
Goodness KR, Renfro NS. Changing a culture: a brief program analysis of a social learning program on a maximum-security forensic unit. Behav Sci Law. 2002;20(5):495-506. [pmid: 12239708].
Goss JR, Peterson K, Smith LW, et al. Characteristics of suicide attempts in a large urban jail system with an established suicide prevention program. Psychiatr Serv. May. 2002;53(5):574-9. [pmid: 11986506].
Greenberg G, Rosenheck RA, Erickson SK, et al. Criminal justice system involvement among people with schizophrenia. Community Ment Health J. Dec. 2011;47(6):727-36. [pmid: 21113799].
Grella CE, Greenwell L, Prendergast M, et al. Diagnostic profiles of offenders in substance abuse treatment programs. Behav Sci Law. 2008;26(4):369-88. [pmid: 18683206].
Gunter TD, Philibert R, Hollenbeck N. Medical and psychiatric problems among men and women in a community corrections residential setting. Behav Sci Law. Sep–Oct. 2009;27(5):695-711. [pmid: 19743513].
Gussak D. Effects of art therapy with prison inmates: a follow-up study. Arts Psychother. 2006;33(3):188-98.
Gussak D. The effectiveness of art therapy in reducing depression in prison populations. Int J Offender Ther Comp Criminol. Aug. 2007;51(4):444-60. [pmid: 17652148].
Hall DL, Miraglia RP, Lee LW, et al. Predictors of general and violent recidivism among SMI prisoners returning to communities in New York State. J Am Acad Psychiatry Law. 2012;40(2):221-31. [pmid: 22635294].
Heap M. Differences in the progress of discharged and undischarged patients in a medium secure unit: a pilot study. J Psychiatr Ment Health Nurs. Oct. 1. 2003;10(5):534-42. [pmid: 12956632].
Heilbrun K, Lawson K, Spier S, et al. Community placement for insanity acquittees: a preliminary study of residential programs and person-situation fit. Bull Am Acad Psychiatry Law. 1994;22(4):551-60. [pmid: 7718928].
Herinckx HA, Swart SC, Ama SM, et al. Rearrest and linkage to mental health services among clients of the Clark County mental health court program. Psychiatr Serv. Jul. 2005;56(7):853-7. [pmid: 16020819].
Hodgins S, Muller-Isberner R, Freese R, et al. A comparison of general adult and forensic patients with schizophrenia living in the community. Int J Forensic Ment Health. 2007;6:63-75.
Hodgins S, Tengstrom AN, Eriksson A, et al. A multisite study of community treatment programs for mentally ill offenders with major mental disorders: design, measures, and the forensic sample. Crim Justice Behav. Feb. 2007;34(2):211-28.
Holcomb WR, Ahr PR. Arrest rates among young adult psychiatric patients treated in inpatient and outpatient settings. Hosp Community Psychiatry. Jan. 1988;39(1):52-7. [pmid: 3338728].
Hornsveld RH, Nijman HL. Evaluation of a cognitive-behavioral program for chronically psychotic forensic inpatients. Int J Law Psychiatry. May–Jun. 2005;28(3):246-54. [pmid: 15950282].
Humber N, Hayes A, Wright S, et al. A comparative study of forensic and general community psychiatric patients with integrated and parallel models of care in the UK. J Forensic Psychiatry Psychol. Apr. 2011;22(2):183-202.
Jerrell JM, Ridgely MS. Evaluating changes in symptoms and functioning of dually diagnosed clients in specialized treatment. Psychiatr Serv. Mar. 1995;46(3):233-8. [pmid: 7796208].
Johnson J, Hickey S. Arrests and incarcerations after psychosocial program involvement: clubhouse vs. jailhouse. Psychiatr Rehabil J. 1999;23(1):66-9.
Johnstone P, Zolese G. Systematic review of the effectiveness of planned short hospital stays for mental health care. BMJ. May. 22. 1999;318(7195):1387-90. [pmid: 10334748].
Johnson J. Cost-effectiveness of mental health services for persons with a dual diagnosis: A literature review and the CCMHCP. J Subst Abuse Treat. Mar. 2000;18(2):119-27. [pmid: 10716095].
Kamath J, Temporini H, Quarti S, et al. Best practices: disseminating best practices for bipolar disorder treatment in a correctional population. Psychiatr Serv. Sep. 2010;61(9):865-7. [pmid: 20810582].
Kamath J, Temporini HD, Quarti S, et al. Psychiatric use and utility of divalproex sodium in Connecticut prisons. Int J Offender Ther Comp Criminol. Jun. 2008;52(3):358-70. [pmid: 17893206].
Kamath J, Zhang W, Kesten K, et al. Algorithm-driven pharmacological management of bipolar disorder in Connecticut prisons. Int J Offender Ther Comp Criminol. 2011. Nov. 24. [pmid: 22116961].
Kinzie DJ, Hancey J, Wilson W, et al. Paroxetine and offenders: a pilot study. Int J Offender Ther Comp Criminol. 1996;40:285-92.
Kleinpeter C, Deschenes EP, Blanks J, et al. Providing recovery services for offenders with co-occurring disorders. J Dual Diagn. Dec. 18. 2006;3(1):59-85.
Kubiak SP, Zeoli AM, Essenmacher L, et al. Transitions between jail and community-based treatment for individuals with co-occurring disorders. Psychiatr Serv. Jun. 2011;62(6):679-81. [pmid: 21632740].
Ladds B, Convit A, Zito J, et al. Involuntary medication of patients who are incompetent to stand trial: a descriptive study of the New York experience with judicial review. Bull Am Acad Psychiatry Law. 1993;21(4):529-45. [pmid: 7914440].
Loveland D, Boyle M. Intensive case management as a jail diversion program for people with a serious mental illness: a review of the literature. Int J Offender Ther Comp Criminol. Apr. 2007;51(2):130-50. [pmid: 17412820].
Lovell D, Allen D, Johnson C, et al. Evaluating the effectiveness of residential treatment for prisoners with mental illness. Crim Justice Behav. 2001;28:83-104.
Lovell D, Johnson C, Jemelka R, et al. Living in prison after residential mental health treatment: a program follow-up. Prison J. 2001;81:473-90.
Luettgen J, Chrapko WE, Reddon JR. Preventing violent re-offending in not criminally responsible patients: an evaluation of a continuity of treatment program. Int J Law Psychiatry. Dec. 1998;21(1):89-98. [pmid: 9526718].
MacKain SJ, Mueser KT. Training in illness self-management for people with mental illness in the criminal justice system. Am J Psychiatr Rehabil. 2009;12:31-56.
MacKain SJ, Streveler A. Social and independent living skills for psychiatric patients in a prison setting: innovations and challenges. Behav Modif. Oct. 1990;14(4):490-518. [pmid: 2252469].
McCoy ML, Roberts DL, Hanrahan P, et al. Jail linkage assertive community treatment services for individuals with mental illnesses. Psychiatr Rehabil J. Winter. 2004;27(3):243-50. [pmid: 14982331].
McMurran M, Egan V, Ahmadi S. A retrospective evaluation of a therapeutic community for mentally disordered offenders. J Forensic Psychiatry. 1998;9(1):103-13.
McPhail ME, Falvo DR, Burker EJ. Psychiatric disorders in incarcerated women: treatment and rehabilitation needs for successful community reentry. J Appl Rehabil Couns. Spr. 2012;43(1):19-26.
Metraux S. Examining relationships between receiving mental health services in the Pennsylvania prison system and time served. Psychiatr Serv. Jul. 2008;59(7):800-2. [pmid: 18586999].
Morgan RD, Fisher WH, Duan N, et al. Prevalence of criminal thinking among state prison inmates with serious mental illness. Law Hum Behav. Aug. 2010;34(4):324-36. [pmid: 19551496].
Morgan RD, Steffan J, Shaw LB, et al. Needs for and barriers to correctional mental health services: inmate perceptions. Psychiatr Serv. Sep. 2007;58(9):1181-6. [pmid: 17766563].
Morris DR, Parker GF. Jackson’s Indiana: state hospital competence restoration in Indiana. J Am Acad Psychiatry Law. 2008;36(4):522-34. [pmid: 19092071].
Morris PJ. Compliance profile of Depakote ER compared to Depakote DR and valproic acid in bipolar patients. J Correct Health Care. Oct. 2008;14(4):311-7.
Newbill WA, Paul GL, Menditto AA, et al. Social-learning programs facilitate an increase in adaptive behavior in a forensic mental hospital. Behav Interv. Jul. 2011;26(3):214-30.
Palacios WR, Urmann CF, Newel R, et al. Developing a sociological framework for dually diagnosed women. J Subst Abuse Treat. Jul–Sep. 1999;17(1–2):91-102. [pmid: 10435256].
Pasic J, Russo J, Roy-Byrne P. High utilizers of psychiatric emergency services. Psychiatr Serv. Jun. 2005;56(6):678-84. [pmid: 15939943].
Pelissier BM, O’Neil JA. Antisocial personality and depression among incarcerated drug treatment participants. J Subst Abuse. 2000;11(4):379-93. [pmid: 11147234].
Pollack LE, Cramer RD, Varner RV. Psychosocial functioning of people with substance abuse and bipolar disorders. Subst Abus. Sep. 2000;21(3):193-203. [pmid: 12466659].
Pomerantz JM. Treatment of the mentally ill in prisons and jails: follow-up care needed. Drug Benefit Trends. Jun. 2003;15(6):20-1.
Redlich AD, Steadman HJ, Robbins PC, et al. Use of the criminal justice system to leverage mental health treatment: effects on treatment adherence and satisfaction. J Am Acad Psychiatry Law. 2006;34(3):292-9. [pmid: 17032951].
Rice ME, Harris GT, Cormier CA. An evaluation of a maximum security therapeutic community for psychopaths and other mentally disordered offenders. Law Hum Behav. 1992;16(4):399-412. Also available: http://www.springerlink.com/content/pp4307834x343812/.
Rosenheck RA, Neale MS. Therapeutic limit setting and six-month outcomes in a Veterans Affairs assertive community treatment program. Psychiatr Serv. Feb. 2004;55(2):139-44. [pmid: 14762237].
Roskes E, Craig R, Strangman A. A prerelease program for mentally ill inmates. Psychiatr Serv. Jan. 2001;52(1):108. [pmid: 11141541].
Ryba NL. Cognitive-behavioral therapy for offender hopelessness: Lessons from treatment of forensic inpatients. J Contemp Psychother. Jun. 2008;38(2):73-80.
Sacks S, Sacks JY, De Leon G. Treatment for MICAs: design and implementation of the modified TC. J Psychoactive Drugs. Jan–Mar. 1999;31(1):19-30. [pmid: 10332635].
Schug RA, Raine A, Wilcox RR. Psychophysiological and behavioural characteristics of individuals comorbid for antisocial personality disorder and schizophrenia-spectrum personality disorder. Br J Psychiatry. Nov. 2007;191:408-14. [pmid: 17978320].
Scott EM. History and treatment efforts for a prison special management unit: III. Prison group therapy with mentally and emotionally disturbed offenders. Int J Offender Ther Comp Criminol. Summer. 1993;37(2):131-45.
Seegert CR. Token economies and incentive programs: Behavioral improvement in mental health inmates housed in state prisons. Behav Ther. Jan. 210. 2003;26(1):208-1.
Shelton D, Wakai S. A process evaluation of START NOW Skills Training for inmates with impulsive and aggressive behaviors. J Am Psychiatr Nurses Assoc. Mar–Apr. 2011;17(2):148-57. [pmid: 21659305].
Sommers I, Baskin DR. Assessing the appropriateness of the prescription of psychiatric medications in prison. J Nerv Ment Dis. May. 1991;179(5):267-73. [pmid: 2022954].
Steadman HJ, Redlich AD, Griffin P, et al. From referral to disposition: case processing in seven mental health courts. Behav Sci Law. 2005;23(2):215-26. [pmid: 15818604].
Taxman FS, Cropsey KL, Melnick G, et al. COD services in community correctional settings: an examination of organizational factors that affect service delivery. Behav Sci Law. 2008;26(4):435-55. [pmid: 18683196].
Tupin JP, Smith DB, Clanon TL, et al. The long-term use of lithium in aggressive prisoners. Compr Psychiatry. Jul–Aug. 1973;14(4):311-7. [pmid: 4724658].
van den Brink RH, Hooijschuur A, van Os TW, et al. Routine violence risk assessment in community forensic mental healthcare. Behav Sci Law. May–Jun. 2010;28(3):396-410. [pmid: 19908211].
Van Dorn RA, Swanson JW, Swartz MS, et al. The effects of race and criminal justice involvement on access to atypical antipsychotic medications among persons with schizophrenia. Ment Health Serv Res. Jun. 2005;7(2):123-34. [pmid: 15974158].
Van Stelle KR, Blumer C, Moberg DP. Treatment retention of dually diagnosed offenders in an institutional therapeutic community. Behav Sci Law. 2004;22(4):585-97. [pmid: 15282841].
Watson MA, Segal SP, Newhill CE. Police referral to psychiatric emergency services and its effect on disposition decisions. Hosp Community Psychiatry. Nov. 1993;44(11):1085-90. [pmid: 8288179].
Weaver T, Taylor F, Cunningham B, et al. The Bentham Unit: a pilot remand and assessment service for male mentally disordered remand prisoners. II: Report of an independent evaluation. Br J Psychiatry. May. 1997;170:462-6. [pmid: 9307698].
Webster SL, Sheitman BB, Barboriak PN, et al. Integrating forensically and civilly committed adult inpatients in a treatment mall program at a state hospital. Psychiatr Serv. Feb. 2009;60(2):262-5. [pmid: 19176424].
Wiederanders, Mark, Choate, Paul A. Beyond recidivism: measuring community adjustments of conditionally released insanity acquittees. Psychol Assess. Mar. 1994;6(1):61-6.
Wiederanders MR. Recidivism of disordered offenders who were conditionally vs. unconditionally released. Behav Sci Law. 1992;10(1):141-8.
Wiederanders MR, Bromley DL, Choate PA. Forensic conditional release programs and outcomes in three states. Int J Law Psychiatry. Spring. 1997;20(2):249-57. [pmid: 9178066].
Wilson S, Attrill G, Nugent F. Effective interventions for acquisitive offenders: an investigation of cognitive skills programmes. Legal Criminol Psychol. Feb. 2003;8(1):83-101.
Wix S. Dialectical behaviour therapy observed. Br J Forensic Pract. May. 2003;5(2):3-8.
Wolff N, Fabrikant N, Belenko S. Mental health courts and their selection processes: modeling variation for consistency. Law Hum Behav. Oct. 2011;35(5):402-12. [pmid: 20976534].
Wolff N, Frueh BC, Shi J, et al. Trauma exposure and mental health characteristics of incarcerated females self-referred to specialty PTSD treatment. Psychiatr Serv. Aug. 2011;62(8):954-8. [pmid: 21807837].
Wormith JS, Olver ME. Offender treatment attrition and its relationship with risk, responsivity and recidivism. Crim Justice Behav. 2002;29(4):447-71.
Yanos PT, Lysaker PH, Roe D. Internalized stigma as a barrier to improvement in vocational functioning among people with schizophrenia-spectrum disorders. Psychiatry Res. Jun. 30. 2010;178(1):211-3. [pmid: 20417973].
Young DS. Non-psychiatric services provided in a mental health unit in a county jail. J Offender Rehabil. 2002;35(2):63-82.
Young S, Chick K, Gudjonsson G. A preliminary evaluation of reasoning and rehabilitation 2 in mentally disordered offenders (R&2R2M) across two forensic settings in the United Kingdom. J Forensic Psychiatry Psychol. 2010;21(3):336.

## Not SMI Population

Alemi F, Haack M, Nemes S, et al. Impact of online counseling on drug use: a pilot study. Qual Manag Health Care. Jan–Mar. 2010;19(1):62-9. [pmid: 20042934].
Ashcraft L, Anthony WA. Prisoners thrive with peer support training. Behav Healthc. Nov–Dec. 2011;31(8):20-3. [pmid: 22283083].
Baker A, Lee NK, Claire M, et al. Brief cognitive behavioural interventions for regular amphetamine users: a step in the right direction. Addiction. Mar. 2005;100(3):367-78. [pmid: 15733250].
Ball SA, Cobb-Richardson P, Connolly AJ, et al. Substance abuse and personality disorders in homeless drop-in center clients: symptom severity and psychotherapy retention in a randomized clinical trial. Compr Psychiatry. Sep–Oct. 2005;46(5):371-9. [pmid: 16122538].
Banerjee K, Howard M, Mansheim K, et al. Comparison of health realization and 12-step treatment in women’s residential substance abuse treatment programs. Am J Drug Alcohol Abuse. Mar. 2007;33(2):207-15. [pmid: 17497543].
Bourgon G, Armstrong B. Transferring the principles of effective treatment into a “Real World” prison setting. Crim Justice Behav. Feb. 2005;32(1):3-25.
Butzin CA, Martin SS, Inciardi JA. Treatment during transition from prison to community and subsequent illicit drug use. J Subst Abuse Treat. Jun. 2005;28(4):351-8. [pmid: 15925269].
Covington SS, Burke C, Keaton S, et al. Evaluation of a trauma-informed and gender-responsive intervention for women in drug treatment. J Psychoactive Drugs. Nov. Suppl 5. 2008:387-98. [pmid: 19248396].
Czuchry M, Dansereau DF. Drug abuse treatment in criminal justice settings: enhancing community engagement and helpfulness. Am J Drug Alcohol Abuse. Nov. 2000;26(4):537-52. [pmid: 11097191].
Desmond DP, Maddux JF. Compulsory supervision and methadone maintenance. J Subst Abuse Treat. Jan–Feb. 1996;13(1):79-83. [pmid: 8699547].
Easton CJ, Weinberger AH, McKee SA. Cigarette smoking and intimate partner violence among men referred to substance abuse treatment. Am J Drug Alcohol Abuse. 2008;34(1):39-46. [pmid: 18161642].
Ferszt GG, Salgado D, DeFedele S, et al. Houses of healing: a group intervention for grieving women in prison. Prison J. Mar. 2009;89(1):46-64.
Flannery RB Jr, Farley E, Rego S, et al. Characteristics of staff victims of psychiatric patient assaults: 15-year analysis of the Assaulted Staff Action Program (ASAP). Psychiatr Q. Mar. 2007;78(1):25-37. [pmid: 17102934].
French MT, McCollister KE, Sacks S, et al. Benefit cost analysis of a modified therapeutic community for mentally ill chemical abusers. Eval Program Plann. May. 2002;25(2):137-148.
Garnick DW, Horgan CM, Lee MT, et al. Are Washington Circle performance measures associated with decreased criminal activity following treatment?. J Subst Abuse Treat. Dec. 2007;33(4):341-52. [pmid: 17524596].
Guydish J, Chan M, Bostrom A, et al. A randomized trial of probation case management for drug-involved women offenders. Crime Delinq. Mar. 2011;57(2):167-98. [pmid: 21464888].
Harner H, Burgess AW. Using a trauma-informed framework to care for incarcerated women. J Obstet Gynecol Neonatal Nurs. Jul–Aug. 2011;40(4):469-76.
Harris GT, Rice ME, Cormier CA. Psychopaths: is a therapeutic community therapeutic?. Ther Communities. 1994;15(4):283-99.
Heseltine K, Howells K, Day A. Brief anger interventions with offenders may be ineffective: A replication and extension. Behav Res Ther. Mar. 2010;48(3):246-50. [pmid: 19896643].
Hoff RA, Rosenheck RA, Baranosky MV, et al. Diversion from jail of detainees with substance abuse: the interaction with dual diagnosis. Am J Addict. Summer. 1999;8(3):201-10. [pmid: 10506901].
Hser YI, Evans E, Huang D, et al. Long-term outcomes among drug-dependent mothers treated in women-only versus mixed-gender programs. J Subst Abuse Treat. Sep. 2011;41(2):115-23. [pmid: 21466942].
Hser YI, Evans E, Teruya C, et al. Predictors of short-term treatment outcomes among California’s Proposition 36 participants. Eval Program Plann. May. 2007;30(2):187-96. [pmid: 17689324].
Hser YI, Stark ME, Paredes A, et al. A 12-year follow-up of a treated cocaine-dependent sample. J Subst Abuse Treat. Apr. 2006;30(3):219-26. [pmid: 16616166].
Hser YI, Teruya C, Evans EA, et al. Treating drug-abusing offenders. Initial findings from a five-county study on the impact of California’s Proposition 36 on the treatment system and patient outcomes. Eval Rev. Oct. 2003;27(5):479-505. [pmid: 14531316].
Hubbard DJ. Getting the most out of correctional treatment: Testing the responsivity principle on male and female offenders. Fed Probat. Jun. 2007;71(1):2-8.
Kellett NC, Willging CE. Pedagogy of individual choice and female inmate reentry in the U.S. Southwest. Int J Law Psychiatry. Jul–Aug. 2011;34(4):256-63. [pmid: 21864909].
Kirby S. Ward atmosphere on a medium secure long-stay ward. J Forensic Psychiatry. 1997;8(2):336-47.
Kline A. Profiles of criminal-justice clients in drug treatment: implications for intervention. Addict Behav. Mar–Apr. 1997;22(2):263-8. [pmid: 9113220].
Leak GK. Effects of highly structured versus nondirective group counseling approaches on personality and behavioral measures of adjustments in incarcerated felons. J Couns Psychol. 1980;27:520-3.
Lowmaster SE, Morey LC, Baker KL, et al. Structure, reliability, and predictive validity of the Texas Christian University correctional residential self-rating form at intake in a residential substance abuse treatment facility. J Subst Abuse Treat. Sep. 2010;39(2):180-87. [pmid: 20598835].
Lynch SM, Heath NM, Mathews KC, et al. Seeking safety: an intervention for trauma-exposed incarcerated women. J Trauma Dissociation. 2012;13(1):88-101. [pmid: 22211443].
Mateyoke-Scrivner A, Webster JM, Staton M, et al. Treatment retention predictors of drug court participants in a rural state. Am J Drug Alcohol Abuse. Aug. 2004;30(3):605-25. [pmid: 15540496].
Maunder L, Cameron L, Moss M, et al. Effectiveness of self-help materials for anxiety adapted for use in prison - a pilot study. J Ment Health. 2009;18(3):262-271.
McGuire J, Rosenheck RA, Kasprow WJ. Health status, service use, and costs among veterans receiving outreach services in jail or community settings. Psychiatr Serv. Feb. 2003;54(2):201-7. [pmid: 12556601].
McNiel DE, Binder RL. Effectiveness of a mental health court in reducing criminal recidivism and violence. Am J Psychiatry. Sep. 2007;164(9):1395-403. [pmid: 17728425].
Melnick G, Coen C, Taxman FS, et al. Community-based co-occurring disorder (COD) intermediate and advanced treatment for offenders. Behav Sci Law. 2008;26(4):457-73. [pmid: 18683204].
Motiuk LL, Blanchette K. Characteristics of administratively segregated offenders in federal corrections. Can J Criminol. Jan. 2001;43(1):131-43.
Muzekari LH, Lonigan CJ, Hatton AY, et al. Mental health services in the county jail: a critical partnership?. Psychol Rep. Jun. 1999;84(3 Pt 2):1099-104. [pmid: 10477928].
Oser C, Knudsen H, Staton-Tindall M, et al. The adoption of wraparound services among substance abuse treatment organizations serving criminal offenders: The role of a women-specific program. Drug Alcohol Depend. Aug. 1. 2009;103(Suppl 1):S82-90. [pmid: 19181457].
Pandiani JA, Ochs WR, Pomerantz AS. Criminal justice involvement of armed forces veterans in two systems of care. Psychiatr Serv. Aug. 2010;61(8):835-7. [pmid: 20675844].
Peat BJ, Winterfree LT. Reducing the intrainstitutional effects of “prisonization”: A study of a therapeutic community for drug-using inmates. Crim Justice Behav. Jun. 1992;19(2):206-25.
Pelissier B, Wallace S, O’Neil JA, et al. Federal prison residential drug treatment reduces substance use and arrests after release. Am J Drug Alcohol Abuse. May. 2001;27(2):315-37. [pmid: 11417942].
Polaschek DL. High-intensity rehabilitation for violent offenders in New Zealand: reconviction outcomes for high- and medium-risk prisoners. J Interpers Violence. Mar. 2011;26(4):664-82. [pmid: 20522892].
Prendergast M, Frisman L, Sacks JY, Staton-Tindall M, Greenwell L, Lin HJ, Cartier J. A multi-site, randomized study of strengths-based case management with substance-abusing parolees. J Exp Criminol. Sep. 2011;7(3):225-53. [pmid: 21949490].
Prendergast ML, Farabee D, Cartier J, et al. Involuntary treatment within a prison setting: impact on psychosocial change during treatment. Crim Justice Behav. Feb. 2002;29(1):5-26.
Richards JM, Beal WE, Seagal JD, et al. Effects of disclosure of traumatic events on illness behavior among psychiatric prison inmates. J Abnorm Psychol. Feb. 2000;109(1):156-60. [pmid: 10740948].
Rowan-Szal GA, Joe GW, Simpson DD, et al. During-treatment outcomes among female methamphetamine-using offenders in prison-based treatments. J Offender Rehabil. Jul. 1. 2009;48(5):388-401. [pmid: 19710949].
Serin RC, Gobeil R, Preston DL. Evaluation of the persistently violent offender treatment program. Int J Offender Ther Comp Criminol. Feb. 2009;53(1):57-73. [pmid: 18281440].
Shelton D, Sampl S, Kesten KL, et al. Treatment of impulsive aggression in correctional settings. Behav Sci Law. Sep–Oct. 2009;27(5):787-800. [pmid: 19784944].
Spiropoulos GV, Spruance L, Van Voorhis P, et al. Pathfinders and problem solving: comparative effects of two cognitive-behavioral programs among men and women offenders in community and prison. J Offender Rehabil. 2005;42(2):69-94.
Stoner SC, Wehner Lea JS, Dubisar BM, et al. Impact of clozapine versus haloperidol on conditional release time and rates of revocation in a forensic psychiatric population. J Pharm Technol. 2002;18(4):182-86.
Strauss SM, Falkin GP. The first week after drug treatment: the influence of treatment on drug use among women offenders. Am J Drug Alcohol Abuse. May. 2001;27(2):241-64. [pmid: 11417938].
Thanner MH, Taxman FS. Responsivity: the value of providing intensive services to high-risk offenders. J Subst Abuse Treat. Mar. 2003;24(2):137-47. [pmid: 12745031].
Trotman AJ, Taxman FS. Implementation of a contingency management-based intervention in a community supervision setting: clinical issues and recommendations. J Offender Rehabil. Jul. 2011;50(5):235-51. [pmid: 22235164].
Turley A, Thornton T, Johnson C, et al. Jail drug and alcohol treatment program reduces recidivism in nonviolent offenders: a longitudinal study of Monroe County, New York’s, Jail Treatment Drug and Alcohol Program. Int J Offender Ther Comp Criminol. Dec. 2004;48(6):721-8. [pmid: 15538028].
Valentine PV. Traumatic incident reduction I: traumatized women inmates: particulars of practice and research. J Offender Rehabil. 2000;31(3–4):1-15.
Valentine PV, Smith TE. Evaluating traumatic incident reduction therapy with female inmates: a randomized controlled clinical trial. Res Soc Work Pract. Jan. 2001;11(1):40-52.
Watson AC, Ottati VC, Draine J, et al. CIT in context: The impact of mental health resource availability and district saturation on call dispositions. Int J Law Psychiatry. Jul. 2011;34(4):287-94. [pmid: 21820177].
Windell PA, Barron N. Treatment preparation in the context of system coordination serves inmates well. J Psychoactive Drugs. Jan–Mar. 2002;34(1):59-67. [pmid: 12003114].
Zlotnick C, Johnson J, Najavits LM. Randomized controlled pilot study of cognitive-behavioral therapy in a sample of incarcerated women with substance use disorder and PTSD. Behav Ther. Dec. 2009;40(4):325-36. [pmid: 19892078].

## Not a Criminal Justice Setting of Interest

Ashford JB, Wong KW, Sternbach KO. Generic correctional programming for mentally ill offenders: a pilot study. Crim Justice Behav. 2008;35(4):457-73. Also available: http://cjb.sagepub.com/content/35/4/457.abstract.
Boccaccini MT, Christy A, Poythress N, et al. Rediversion in two postbooking jail diversion programs in Florida. Psychiatr Serv. Jul. 2005;56(7):835-9. [pmid: 16020816].
Broner N, Mayrl DW, Landsberg G. Outcomes of mandated and nonmandated New York City jail diversion for offenders with alcohol, drug, and mental disorders. Prison J. Mar. 2005;85(1):18-49.
Brown S, Bass N. The psychiatric intensive care unit (PICU): Patient characteristics, treatment and outcome. J Ment Health. Dec. 2004;13(6):601-9.
Calsyn RJ, Yonker RD, Lemming MR, et al. Impact of assertive community treatment and client characteristics on criminal justice outcomes in dual disorder homeless individuals. Crim Behav Ment Health. 2005;15(4):236-48. [pmid: 16575844].
Chandler D, Meisel J, Hu TW, et al. Client outcomes in a three-year controlled study of an integrated service agency model. Psychiatr Serv. Dec. 1996;47(12):1337-43. [pmid: 9117472].
Christy A, Poythress NG, Boothroyd RA, et al. Evaluating the efficiency and community safety goals of the Broward County Mental Health Court. Behav Sci Law. 2005;23(2):227-43. [pmid: 15818603].
Clarke GN, Herinckx HA, Kinney RF, et al. Psychiatric hospitalizations, arrests, emergency room visits and homelessness of clients with serious and persistent mental illness: findings from a randomized trial of two ACT programs vs. usual care. Ment Health Serv Res. Sep. 2000;2(3):155-64. [pmid: 11256724].
Cosden M, Ellens J, Schnell J, et al. Efficacy of a mental health treatment court with assertive community treatment. Behav Sci Law. 2005;23(2):199-214. [pmid: 15818609].
Cosden M, Ellens JK, Schnell JL, et al. Evaluation of a mental health treatment court with assertive community treatment. Behav Sci Law. 2003;21(4):415-27. [pmid: 12898500].
Cusack KJ, Morrissey JP, Cuddeback GS, et al. Criminal justice involvement, behavioral health service use, and costs of forensic assertive community treatment: a randomized trial. Community Ment Health J. Aug. 2010;46(4):356-63. [pmid: 20217230].
DiNitto DM, Webb DK, Rubin A. The effectiveness of an integrated treatment approach for clients with dual diagnoses. Res Soc Work Pract. Sep. 2002;12(5):621-41.
Drake RE, McHugo GJ, Clark RE, et al. Assertive community treatment for patients with co-occurring severe mental illness and substance use disorder: a clinical trial. Am J Orthopsychiatry. Apr. 1998;68(2):201-15. [pmid: 9589759].
Essock SM, Mueser KT, Drake RE, et al. Comparison of ACT and standard case management for delivering integrated treatment for co-occurring disorders. Psychiatr Serv. Feb. 2006;57(2):185-96. [pmid: 16452695].
Frailing K. How mental health courts function: outcomes and observations. Int J Law Psychiatry. Sep. 2010;33(4):207-13. [pmid: 20667593].
Frisman LK, Lin HS, Sturges GE, et al. Outcomes of court-based jail diversion programs for people with co-occurring disorders. J Dual Diagn. 2006;2(2):5-26.
Frisman LK, Mueser KT, Covell NH, et al. Use of integrated dual disorder treatment via assertive community treatment versus clinical case management for persons with co-occurring disorders and antisocial personality disorder. J Nerv Ment Dis. Nov. 2009;197(11):822-8. [pmid: 19996720].
Gilmer TP, Stefancic A, Ettner SL, et al. Effect of full-service partnerships on homelessness, use and costs of mental health services, and quality of life among adults with serious mental illness. Arch Gen Psychiatry. Jun. 2010;67(6):645-52. [pmid: 20530014].
Hiday VA, Swartz MS, Swanson JW, et al. Impact of outpatient commitment on victimization of people with severe mental illness. Am J Psychiatry. Aug. 2002;159(8):1403-11. [pmid: 12153835].
Hoff RA, Baranosky MV, Buchanan J, et al. The effects of a jail diversion program on incarceration: a retrospective cohort study. J Am Acad Psychiatry Law. 1999;27(3):377-86. [pmid: 10509937].
Hough WG, O’Brien KP. The effect of community treatment orders on offending rates. Psychiatr Psychol Law. 2005;12(2):411-23.
Leff J, Dayson D, Gooch C, et al. Quality of life of long-stay patients discharged from two psychiatric institutions. Psychiatr Serv. Jan. 1996;47(1):62-7. [pmid: 8925348].
LePage JP, Washington EL, Lewis AA, et al. Effects of structured vocational services on job-search success in ex-offender veterans with mental illness: 3-month follow-up. J Rehabil Res Dev. 2011;48(3):277-86. [pmid: 21480102].
Moore ME, Hiday VA. Mental health court outcomes: a comparison of re-arrest and re-arrest severity between mental health court and traditional court participants. Law Hum Behav. Dec. 2006;30(6):659-74. [pmid: 17053948].
Pollack DA, McFarland BH, Mahler JM, et al. Outcomes of patients in a low-intensity, short-duration involuntary outpatient commitment program. Psychiatr Serv. Jul. 2005;56(7):863-6. [pmid: 16020821].
Ries RK, Comtois KA. Managing disability benefits as part of treatment for persons with severe mental illness and comorbid drug/alcohol disorders. A comparative study of payee and non-payee participants. Am J Addict. 1997;6(4):330-8. [pmid: 9398931].
Rivas-Vazquez RA, Sarria M, Rey G, et al. A relationship-based care model for jail diversion. Psychiatr Serv. Jun. 2009;60(6):766-71. [pmid: 19487345].
Rowe M, Bellamy C, Baranoski M, et al. A peer-support, group intervention to reduce substance use and criminality among persons with severe mental illness. Psychiatr Serv. Jul. 2007;58(7):955-61. [pmid: 17602012].
Steadman HJ, Redlich A, Callahan L, et al. Effect of mental health courts on arrests and jail days: a multisite study. Arch Gen Psychiatry. Feb. 2011;68(2):167-72. [pmid: 20921111].
Swanson JW, Borum R, Swartz MS, et al. Can involuntary outpatient commitment reduce arrests among persons with severe mental illness?. Crim Justice Behav. Apr. 2001;28(2):156-89.
Swartz MS, Swanson JW, Hiday VA, et al. A randomized controlled trial of outpatient commitment in North Carolina. Psychiatr Serv. Mar. 2001;52(3):325-9. [pmid: 11239099].
Wolff N, Helminiak TW, Morse GA, et al. Cost-effectiveness evaluation of three approaches to case management for homeless mentally ill clients. Am J Psychiatry. Mar. 1997;154(3):341-8. [pmid: 9054781].

## No Treatment Tested

Axelson GL, Wahl OF. Psychotic versus nonpsychotic misdemeanants in a large county jail: an analysis of pretrial treatment by the legal system. Int J Law Psychiatry. 1992;15(4):379-86. [pmid: 1428421].
Bloom JD, Williams MH, Bigelow DA. The involvement of schizophrenic insanity acquittees in the mental health and criminal justice systems. Psychiatr Clin North Am. 1992;15(3):591-604. [pmid: 1409023].
Fisher WH, Dickey B, Normand SL, et al. Use of a state inpatient forensic system under managed mental health care. Psychiatr Serv. Apr. 2002;53(4):447-51. [pmid: 11919358].
Harris GT, Rice ME, Cormier CA. Length of detention in matched groups of insanity acquittees and convicted offenders. Int J Law Psychiatry. 1991;14(3):223-36. [pmid: 1864689].
Hartwell SW, Fisher WH, Deng X. The impact of regionalization on reentry service outcomes for individuals with severe mental illness. Psychiatr Serv. Mar. 2009;60(3):394-7. [pmid: 19252055].
Hillbrand M, Krystal JH, Sharpe KS, et al. Clinical predictors of self-mutilation in hospitalized forensic patients. J Nerv Ment Dis. Jan. 1994;182(1):9-13. [pmid: 8277305].
Hiller ML, Webster JM, Garrity TF, et al. Prisoners with substance abuse and mental health problems: use of health and health services. Am J Drug Alcohol Abuse. 2005;31(1):1-20. [pmid: 15768568].
Jackson DO, Mrug S, Cook F, et al. Factors predicting substance dependence and psychotropic medication use among offenders in community corrections. Addict Behav. Jul. 2011;36(7):755-8. [pmid: 21367532].
Levitt GA, Vora I, Tyler K, et al. Civil commitment outcomes of incompetent defendants. J Am Acad Psychiatry Law. 2010;38(3):349-58. [pmid: 20852220].
Morrissey JP, Cuddeback GS, Cuellar AE, et al. The role of Medicaid enrollment and outpatient service use in jail recidivism among persons with severe mental illness. Psychiatr Serv. Jun. 2007;58(6):794-801. [pmid: 17535939].
Morrissey JP, Steadman HJ, Dalton KM, et al. Medicaid enrollment and mental health service use following release of jail detainees with severe mental illness. Psychiatr Serv. Jun. 2006;57(6):809-15. [pmid: 16754757].
Nelson EL, Zaylor C, Cook D. A comparison of psychiatrist evaluation and patient symptom report in a jail telepsychiatry clinic. Telemed J E Health. 2004;10(Suppl 2):S54-9.
Ray B, Dollar CB, Thames KM. Observations of reintegrative shaming in a mental health court. Int J Law Psychiatry. Jan–Feb. 2011;34(1):49-55. [pmid: 21122916].
Shafer MS, Arthur B, Franczak MJ. An analysis of post-booking jail diversion programming for persons with co-occurring disorders. Behav Sci Law. 2004;22(6):771-85. [pmid: 15386559].
Shah PJ, Greenberg WM, Convit A. Hospitalized insanity acquittees’ level of functioning. Bull Am Acad Psychiatry Law. 1994;22(1):85-93. [pmid: 8193392].
Skegg K, Cox B. Impact of psychiatric services on prison suicide. Lancet. Dec. 7. 1991;338(8780):1436-8. [pmid: 1683429].
Steadman HJ, Cocozza JJ, Veysey BM. Comparing outcomes for diverted and nondiverted jail detainees with mental illnesses. Law Hum Behav. Dec. 1999;23(6):615-27. [pmid: 10633579].
Stewart LA. Profile of female firesetters. Implications for treatment. BJP Rev Books. Aug. 1993;163:248-56. [pmid: 8075918].
Weaver T, Taylor F, Cunningham B, et al. Impact of a dedicated service for male mentally disordered remand prisoners in north west London: retrospective study. BMJ. Apr. 26. 1997;314(7089):1244-5. [pmid: 9154028].
Zeiss RA, Tanke ED, Fenn HH, et al. Dangerousness commitments: indices of future violence potential?. Bull Am Acad Psychiatry Law. 1996;24(2):247-53. [pmid: 8807164].

## Less Than 3 Month Followup

Beck-Sander A, Griffiths A, Friel C. A group-based intervention for forensic patients recovering from psychosis. Crim Behav Ment Health. Sep. 1998;8(3):193-201.
Brodey BB, Claypoole KH, Motto J, et al. Satisfaction of forensic psychiatric patients with remote telepsychiatric evaluation. Psychiatr Serv. Oct. 2000;51(10):1305-7. [pmid: 11013332].
Clarke AY, Cullen AE, Walwyn R, et al. A quasi-experimental pilot study of the reasoning and rehabilitation programme with mentally disordered offenders. J Forensic Psychiatry Psychol. Aug. 2010;21(4):490-500.
Gussak D. The effects of art therapy on male and female inmates: advancing the research base. Arts Psychother. Feb. 2009;36(1):5-12.
Jarrett M, Thornicroft G, Forrester A, et al. Continuity of care for recently released prisoners with mental illness: a pilot randomised controlled trial testing the feasibility of a Critical Time Intervention. Epidemiol Psychiatr Sci. Jun. 2012;21(2):187-93. [pmid: 22789168].
Morgan RD, Patrick AR, Magaletta PR. Does the use of telemental health alter the treatment experience? Inmates’ perceptions of telemental health versus face-to-face treatment modalities. J Consult Clin Psychol. Feb. 2008;76(1):158-62. [pmid: 18229993].

## No Baseline Matching

Broner N, Lattimore PK, Cowell AJ, et al. Effects of diversion on adults with co-occurring mental illness and substance use: outcomes from a national multi-site study. Behav Sci Law. 2004;22(4):519-41. [pmid: 15282838].
Castillo ED, Alarid LF. Factors associated with recidivism among offenders with mental illness. Int J Offender Ther Comp Criminol. Feb. 2011;55(1):98-117. [pmid: 20181775].
Lattimore PK, Broner N, Sherman R, et al. A comparison of prebooking and postbooking diversion programs for mentally ill substance-using individuals with justice involvement. J Contemp Crim Justice. Feb. 2003;19(1):30-64.
Livingston JD, Rossiter KR, Verdun-Jones SN. ‘Forensic’ labelling: an empirical assessment of its effects on self-stigma for people with severe mental illness. Psychiatry Res. Jun. 30. 2011;188(1):115-22. [pmid: 21333361].
Swaminath RS, Mendonca JD, Vidal C, et al. Experiments in change: pretrial diversion of offenders with mental illness. Can J Psychiatry. Jun. 2002;47(5):450-8. [pmid: 12085680].

## Country

Aho-Mustonen K, Tiihonen J, Repo-Tiihonen E, et al. Group psychoeducation for long-term offender patients with schizophrenia: an exploratory randomised controlled trial. Crim Behav Ment Health. Jul. 2011;21(3):163-76. [pmid: 20859932].
Kerepcic I, Koludrovic M, Jurin M, et al. Clozapine in treatment of schizophrenic heteroaggressive forensic patients. Psychiatria Danubina. 1994;6(1–2):105-8.
Schippers GM, Marker N, Fuentasas-Merillas L. Social skills training, prosocial behavior, and aggressiveness in adult incarcerated offenders. Int J Offender Ther Comp Criminol. 2001;45(2):244-51.
van den Broek E, Keulen-de Vos M, Bernstein DP. Arts therapies and Schema Focused therapy: a pilot study. Arts Psychother. Nov. 2011;38(5):325-332.

## No Mental Health Outcome Reported

Friendship C, Blud L, Erikson M, et al. Cognitive-behavioural treatment for imprisoned offenders: an evaluation of HM prison service’s cognitive skills programmes. Legal Criminol Psychol. Feb. 2003;8(1):103-14.
Kesten KL, Leavitt-Smith E, Rau DR, et al. Recidivism rates among mentally ill inmates: impact of the Connecticut offender reentry program. J Correct Health Care. Jan. 2012;18(1):20-8. Epub 2011 Nov 17. [pmid: 22095006].
Sacks S, Chaple M, Sacks JY, et al. Randomized trial of a reentry modified therapeutic community for offenders with co-occurring disorders: Crime outcomes. J Subst Abuse Treat. Apr. 2012;42(3):247-59. Epub 2011 Sept 22. [pmid: 21943810].
Swinton M, Haddock A. Clozapine in special hospital: a retrospective case-control study. J Forensic Psychiatry. 2000;11(3):587-96.

## No Validated Instrument Used

Sahota S, Davies S, Duggan C, et al. The fate of medium secure patients discharged to generic or specialised services. J Forensic Psychiatry Psychol. 2009;20(1):74-84.
Siberski J. Response of psychiatrically impaired inmates to activity therapy. J Offender Rehabil. 2001;33(3):65-73.
Thaut MH. The influence of music therapy interventions on self-related changes in relaxation, affect, and thought in psychiatric prisoner-patients. J Music Ther. 1989;26:155-66.

## Out of Publication Date Range

Silver SB, Cohen MI, Spodak MK. Follow-up after release of insanity acquittees, mentally disordered offenders, and convicted felons. Bull Am Acad Psychiatry Law. 1989;17(4):387-400. [pmid: 2605365].
Solomon P, Draine J, Meyerson A. Jail recidivism and receipt of community mental health services. Hosp Community Psychiatry. Aug. 1994;45(8):793-7. [pmid: 7982695].
Tellefsen C, Cohen MI, Silver SB, et al. Predicting success on conditional release for insanity acquittees: regionalized versus nonregionalized hospital patients. Bull Am Acad Psychiatry Law. 1992;20(1):87-100. [pmid: 1576378].

## Duplicate

Coid J, Kahtan N, Gault S, et al. Medium secure forensic psychiatry services: comparison of seven English health regions. Br J Psychiatry. Jan. 2001;178(1):55-61. [pmid: 11136211].
Sacks JY, Sacks S, McKendrick K, et al. Prison therapeutic community treatment for female offenders: profiles and preliminary findings for mental health and other variables (crime, substance use and HIV risk). J Offender Rehabil. 2008;46(3):233-61. Also available: http://www.tandfonline.com/doi/abs/10.1080/10509670802143680.