# Forms Used for Title, Abstract, and Full-length Article Review

Table B1 Questions used for title, abstract, and full-length article review

Review Level | Questions | Answer Choices
Title screening | Does the title of the article address the topic of the report? | Yes
Title screening | Does the title of the article address the topic of the report? | No
Abstract screening | Does the abstract meet any of the following exclusion criteria? | Off-topic
Abstract screening | Does the abstract meet any of the following exclusion criteria? | Non-English language
Abstract screening | Does the abstract meet any of the following exclusion criteria? | Not a full length article
Abstract screening | Does the abstract meet any of the following exclusion criteria? | Case report (<5 subjects)
Abstract screening | Does the abstract meet any of the following exclusion criteria? | Study of Children
Abstract screening | Does the abstract meet any of the following exclusion criteria? | None of the above
Abstract screening | Was the study conducted in a country of interest? | Yes
Abstract screening | Was the study conducted in a country of interest? | No
Abstract screening | Was the study conducted in a country of interest? | Unsure
Abstract screening | Is this a nonclinical study (narrative or systematic review) but looks like it might be useful anyway? | Yes
Abstract screening | Is this a nonclinical study (narrative or systematic review) but looks like it might be useful anyway? | No
Abstract screening | Is this a nonclinical study (narrative or systematic review) but looks like it might be useful anyway? | Unsure
Abstract screening | Is this a nonclinical study (narrative or systematic review) but looks like it might be useful anyway? | Clinical study
Abstract screening | Is the study a comparative trial with an independent control group? | Yes
Abstract screening | Is the study a comparative trial with an independent control group? | No
Abstract screening | Is the study a comparative trial with an independent control group? | Unsure
Abstract screening | Is the study a comparative trial with an independent control group? | Not applicable
Abstract screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | Yes
Abstract screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | No
Abstract screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | Unsure
Abstract screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | Not applicable
Abstract screening | Is the study population primarily SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a dual diagnosis of substance abuse? | Yes
Abstract screening | Is the study population primarily SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a dual diagnosis of substance abuse? | No
Abstract screening | Is the study population primarily SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a dual diagnosis of substance abuse? | Unsure
Abstract screening | Is the study population primarily SMI (schizophrenia, schizoaffective disorder, bipolar disorder, or major depression) with or without a dual diagnosis of substance abuse? | Not applicable
Abstract screening | Does the study appear to be conducted in one of the CJ settings of interest? | Yes
Abstract screening | Does the study appear to be conducted in one of the CJ settings of interest? | No
Abstract screening | Does the study appear to be conducted in one of the CJ settings of interest? | Unsure
Abstract screening | Does the study appear to be conducted in one of the CJ settings of interest? | Not applicable
Abstract screening | Does the study follow patients for at least 3 months? | Yes
Abstract screening | Does the study follow patients for at least 3 months? | No
Abstract screening | Does the study follow patients for at least 3 months? | Unsure
Abstract screening | Does the study follow patients for at least 3 months? | Not applicable
Article screening | Is the study published in English? | Yes
Article screening | Is the study published in English? | No
Article screening | Is the study a peer-reviewed full-length article or from an important gray literature agency? | Yes
Article screening | Is the study a peer-reviewed full-length article or from an important gray literature agency? | No
Article screening | Was the study conducted in a country of interest? | Yes
Article screening | Was the study conducted in a country of interest? | No
Article screening | Is the study population 18 years or older? | Yes
Article screening | Is the study population 18 years or older? | No
Article screening | Is the study population SMI or SMI plus substance abuse/use disorder? | Yes
Article screening | Is the study population SMI or SMI plus substance abuse/use disorder? | No
Article screening | Is the study a comparative trial with an independent control group? | Yes
Article screening | Is the study a comparative trial with an independent control group? | No
Article screening | Does the study include 5 patients per treatment arm? | Yes
Article screening | Does the study include 5 patients per treatment arm? | No
Article screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | Yes
Article screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | No
Article screening | Does the study consider the efficacy/effectiveness of a treatment/intervention/program? | Unsure
Article screening | If not randomized, does the study use an analytic method (i.e., baseline matching, propensity scoring, etc.) to address selection bias? | Yes
Article screening | If not randomized, does the study use an analytic method (i.e., baseline matching, propensity scoring, etc.) to address selection bias? | No
Article screening | Does the study appear to be conducted in one of the CJ settings of interest? | Yes
Article screening | Does the study appear to be conducted in one of the CJ settings of interest? | No
Article screening | Does the study follow patients for at least 3 months? | Yes
Article screening | Does the study follow patients for at least 3 months? | No
Article screening | Does the study report on at least one mental health outcome? | Yes
Article screening | Does the study report on at least one mental health outcome? | No
Article screening | Are subjective outcomes measured using validated instruments? | Yes
Article screening | Are subjective outcomes measured using validated instruments? | No
Article screening | Other reason for exclusion? | Duplicate
Article screening | Other reason for exclusion? | Out of publication date range
Article screening | Other reason for exclusion? | Other (specify)
Article screening | Which Key Question does the study answer? | Key Question 1
Article screening | Which Key Question does the study answer? | Key Question 2
Article screening | What is the primary study population? | SMI
Article screening | What is the primary study population? | Dual Diagnosed
Article screening | What is the primary study population? | Mixed Population

CJ=Criminal justice; SMI=serious mental illness