# Literature Search Methods

## Electronic Database Searches

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for the bibliographic databases appear below.

Table A1 Electronic database searches

Name | Date Limits | Platform/Provider
ClinicalTrials.gov | Through September 20, 2012 | U.S. National Institutes of Health
The Cochrane Central Register of Controlled Trials (CENTRAL) | 1990 through 2012, Issue 8 | Wiley
The Cochrane Database of Methodology Reviews (Methodology Reviews) | 1990 through 2012, Issue 8 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | 1990 through 2012, Issue 8 | Wiley
Database of Abstracts of Reviews of Effects (DARE) | 1990 through 2012, Issue 8 | Wiley
EMBASE (Excerpta Medica) | 1990 through August 20, 2012 | OvidSP
Health Technology Assessment Database (HTA) | 1990 through 2012, Issue 8 | Wiley
Healthcare Standards Directory (ECRI Institute) | Through September 10, 2012 | ECRI Institute
MEDLINE/PreMEDLINE | 1990 through August 20, 2012 | Ovid SP
National Criminal Justice Reference Service (NCJRS) | 1990 through September 11, 2012 | U.S. Department of Justice
ProQuest Criminal Justice | 1990 through September 20, 2012 | ProQuest
PsycINFO | 1990 through August 20, 2012 | Ovid SP
PubMed (In-process and Publisher records) | 1990 through August 20, 2012 | U.S. National Library of Medicine
U.K. National Health Service Economic Evaluation Database (NHS EED) | 1990 through 2012, Issue 8 | Wiley
U.S. National Guideline Clearinghouse™ (NGC) | Through September 20, 2012 | Agency for Healthcare Research and Quality (AHRQ)

Detailed search strategies are presented below.

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

## Medical Subject Headings (MeSH), EMTREE, PsycINFO, and Keywords

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the concepts shown in the Topic-specific Search Terms table.

Table A2 Topic-specific search terms

Concept | Controlled Vocabulary | Keywords
Serious mental illness and dual diagnosis | MEDLINE (MeSH) Depression/ Diagnoses dual/ Exp mood disorders/ Exp schizophrenia and disorders with psychotic features/ Mental disorders/ Mentally ill persons/ EMBASE (EMTREE) ((Exp addiction/OR Exp substance abuse/) AND comorbidity/) Exp mood disorder/ Exp psychosis/ Mental disease/ PsycINFO Dual diagnosis/ Exp affective disorders/ Exp chronic mental illness/ Exp psychosis/ Mental disorders/ Schizoaffective disorder/ | Affective disorder/s Bipolar Co-occurring Depression Depressive Dual diagnosis/es Dual disorder/s Dually diagnosed MDD Mental disorder/s Mental illness/es Mentally disordered Mentally ill MICA Mood disorder/s Psychiatric disorder/s Psychosis/es Psychotic Schizoaffective Schizophren^*^ SMI SPMI
Criminal justice system | MEDLINE Criminals/ Prisoners/ Prisons/ EMBASE Offender/ Prison/ Prisoner/ PsycINFO Correctional institutions/ Exp criminals/ Incarceration/ Mentally ill offenders/ Prisoners/ | Correctional Criminal^*^ Forensic hospital/s Forensic setting/s High secure/ity Incarcerated Incarceration Inmate^*^ Jail^*^ Low secure/ity Medium secure/ity Offender^*^ Parole^*^ Prison/s Prisoner/s Probation^*^
Re-entry | | Discharge planning Reentering Re-entering Reentrance Re-entrance Reentry Re-entry Reintegrating Re-integrating Reintegration Re-integration Releas^*^ Return to society
Psychiatric interventions and delivery of services | MEDLINE Case management/ Community mental health services/ Exp forensic psychiatry/ Exp mandatory programs/ Exp medical assistance/ Exp program evaluation/ Exp psychotherapy Exp self-help groups/ Mental health services/ ^*^Psychiatry/ Voluntary programs/ EMBASE Case management/ Community based rehabilitation/OR Community care/ Community program/ Counseling/ Exp psychotherapy/ Forensic psychiatry/ Medicaid/ Medicare/ Mental health service/ Program development/ Psychiatric treatment/ ^*^Psychiatry/ Social psychiatry/ Support group/ Voluntary program/ PsycINFO Cognitive therapy/ Community mental health centers/ Community mental health services/ Counseling/ Crisis intervention/ Exp ^*^intervention/ Exp case management/ Exp program development/ Exp program evaluation/ Exp psychotherapy/ Forensic psychiatry/ Involuntary treatment/ Medicaid/OR medicare/ Mental health programs/ Motivational interviewing/ Outpatient commitment/ Outpatient treatment/ ^*^Psychiatry/ Support groups/ | Aftercare After-care Assertive community treatment Case management Cognitive behavior/al therapy Cognitive behavior/al treatment Cognitive behaviour/al therapy Cognitive behaviour/al treatment Cognitive therapy Community-based program Community-based treatment Complementary Counseling Criminal thinking curricula Critical time intervention Dialectical Forensic psychiatry Group intervention Group support IDDT Integrated dual disorders treatment Intensive community treatment Meditat^*^ Mental health team/s Modified therapeutic community Motivational interviewing Outpatient commitment Outpatient treatment Psychiatric treatment Psychoeducation^*^ Psychotherapy Seeking safety Strengths-based care management Support group/s Trauma informed interventions Trauma recovery and empowerment model Trauma-informed services Treatment alternatives for safer communities [underlined: Broad terms]: Intervention^*^ Medicaid Medical assistance Medical benefits Medicare Program^*^ Rehabilitation Service^*^ Social security disability insurance SSI Supplemental security income Therap^*^ Treatment^*^
Pharmacologic interventions | MEDLINE Anti-anxiety agents/ Antimanic agents/ Antipsychotic agents/ Drug therapy.fs. Drug therapy/ Exp antidepressive agents/ Psychotropic drugs/ Therapeutic use.fs. EMBASE Drug therapy.fs. Drug therapy/ Exp antidepressant agent/ Exp anxiolytic agent/ Exp benzodiazepine derivative/ Exp neuroleptic agent/ Psychopharmacotherapy/ Psychotropic agent/ PsycINFO Benzodiazepines/ Drug therapy/ Exp antidepressant drugs/ Exp neuroleptic drugs/ | Antidepressant^*^ Anti-depressant/s Antipsychotic^*^ Anti-psychotic/s Benzodiazepine^*^ Drug counseling Drug therapy Drug treatment/s Drug-based Incarceration-based drug treatment Mood stabiliser/s Mood stabilizer/s Pharmacologic^*^ Psychopharmacologic^*^ Psychotropic/s Risperidone Serotonin reuptake inhibitor/s SSRIs Substance abuse treatment

## Search Strategies

The strategy below is presented in OVID syntax; the search was simultaneously conducted across EMBASE, MEDLINE, and PsycINFO. A similar strategy was used to search the databases comprising the Cochrane Library, ProQuest Criminal Justice, and NCJRS.

### OVID Conventions

^*^: when appearing before a search term requires the term to be a “major” heading
^*^: when appearing at the end of a search term signifies truncation (wildcard)
ADJn: search terms within a specified number (n) of words from each other in any order
exp: “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)
.de.: limit controlled vocabulary heading
.fs.: floating subheading
.hw.: limit to heading word
.md.: type of methodology (PsycINFO)
.mp.: combined search fields (default if no fields are specified)
.pt.: publication type
.ti.: limit to title
.tw.: limit to title and abstract fields

Table A3 EMBASE/MEDLINE/PsycINFO – OVID Syntax

Set # | Concept | Search Statement
1 | Mentally ill population | Mental disease/ OR mental disorders/ OR mentally ill persons/ OR exp chronic mental illness/ OR exp affective disorders/ OR depression/ OR exp mood disorder/ OR exp mood disorders/ OR exp psychosis/ OR schizoaffective disorder/ OR exp schizophrenia and disorders with psychotic features/ OR ((mental^*^ OR psychiatric) ADJ (disorder^*^ OR health OR ill OR illness^*^)) OR SMI OR SPMI OR (affective ADJ disorder^*^) OR bipolar OR depress^*^ OR MDD OR (mood ADJ disorder^*^) OR psychosis OR psychoses OR psychotic OR schizoaffective OR schizophreni^*^
2 | Dually diagnosed population | Diagnosis dual/ OR ((exp addiction/ OR exp substance abuse/) AND comorbidity/) OR dual diagnosis/ OR (co ADJ occurring) OR comorbid^*^ OR (dual^*^ ADJ (diagnos^*^ OR disorder^*^)) OR MICA.ti,ab.
3 | Criminal justice population | Exp criminals/ OR exp correctional institutions/ OR incarceration/ OR offender/ OR exp prison/ OR exp prisons/ OR prisoner/ OR prisoners/ OR correctional OR criminal^*^ OR incarcerat^*^ OR inmate^*^ OR (offender^*^ NOT sex^*^.ti.) OR high secure OR low secure OR medium secure OR jail^*^ OR parole^*^ OR prison OR prisons OR (prisoner^*^ NOT (political^*^ OR war).ti.) OR probation^*^
4 | Concepts that cover both populations | mentally ill offenders/ OR (forensic ADJ (hospital^*^ OR patients OR setting^*^ OR unit OR units))
5 | Psychiatric interventions Subject headings | Exp forensic psychiatry/ OR *psychiatry/ OR psychiatric treatment/ OR exp psychotherapy/ OR cognitive therapy/ OR exp complementary therapies/ OR counseling/ OR exp case management/ OR crisis intervention/ OR *intervention/ OR group intervention/ OR self help/ OR exp self-help groups/ OR self help techniques/ OR social psychiatry/ OR support group/ OR support groups/ OR group intervention/ OR mental health programs/ OR mental health services/ OR motivational interviewing/ OR involuntary treatment/ OR exp mandatory programs/ OR voluntary program/ OR voluntary programs/OR exp program development/ OR exp program evaluation/ OR community based rehabilitation/ OR community care/ OR community mental health centers/ OR community mental health services/ OR community program/ OR outpatient treatment/ OR telepsychiatry/
6 | Psychiatric interventions Text words | Aftercare OR after care OR assertive case management OR assertive community treatment OR (case management).ti. OR cognitive therapy OR (cognitive ADJ behav^*^ ADJ (therapy OR treatment)) OR CBT OR (community based).ti. OR community treatment OR complementary OR counseling OR (crisis ADJ intervention ADJ team^*^) OR critical thinking curricula OR critical time intervention OR dialectical.ti. OR forensic psychiatry OR (group^*^ ADJ (intervention^*^ OR support^*^ OR therapy)) OR (support ADJ group^*^) OR integrated dual disorders treatment OR IDDT OR (intensive ADJ community ADJ treatment^*^) OR intensive supervision OR meditat^*^ OR mindfulness based relapse prevention OR modified therapeutic community OR motivational interviewing OR psychoeducation^*^ OR psychotherap^*^ OR psychiatry.ti. OR self help OR seeking safety OR strengths based case management OR trauma informed OR (trauma ADJ recovery ADJ2 empowerment) OR TREM OR outpatient commitment OR outpatient treatment OR (treatment ADJ alternatives ADJ2 safer ADJ communities) OR telemental OR telepsychiatry OR telepsychology OR (intervention^*^ OR program^*^ OR rehabilitat^*^ OR service^*^ OR treat^*^ OR therap^*^).ti.
7 | Pharmacologic interventions Subject headings | Exp anxiolytic agent/ OR exp anticonvulsants/ OR exp anticonvulsive agent/ OR exp anticonvulsive drugs/ OR exp antidepressant agent/ OR exp antidepressive agents/ OR exp antidepressant drugs/ OR anti-anxiety agents/ OR antimanic agents/ OR antipsychotic agents/ OR exp benzodiazepine derivative/ OR benzodiazepines/ OR drug therapy/ OR drug therapy.fs. OR exp neuroleptic agent/ OR exp neuroleptic drugs/ OR psychopharmacotherapy/ OR psychotropic agent/ OR psychotropic drugs/
8 | Pharmacologic interventions Text words | (drug ADJ (based OR counseling OR therapy OR treatment^*^)) OR formular^*^ OR medication^*^ OR pharmac^*^ OR psychopharmacologic^*^ OR psychopharmacotherap^*^ OR (substance ADJ abuse ADJ treatment^*^) OR agonist^*^ OR anticonvulsant^*^ OR anticonvulsive^*^ OR antidepress^*^ OR (anti ADJ depress^*^) OR antipsychotic^*^ OR (anti ADJ psychotic^*^) OR benzodiazepine^*^ OR (mood ADJ (stabiliser^*^ OR stabilizer^*^)) OR psychotropic^*^ OR risperidone OR (serotonin ADJ reuptake ADJ inhibitor^*^) OR SSRI^*^
9 | Benefits | Exp medical assistance/ OR medicaid OR medicare/ OR medical assistance OR medical benefits OR medicaid OR medicare OR supplemental security income OR SSI OR social security disability insurance
10 | Combine intervention and benefits sets | OR/5–9
11 | Community re-entry population | Discharge planning OR reentry OR re entry OR reentering OR re entering OR reentrance OR re entrance OR reintegration OR re integration OR releas^*^ OR (return ADJ2 society)
12 | Key question 1 | (((1 OR 2) AND 3) OR 4) AND 10
13 | Key question 2 | (((1 OR 2) AND 3) OR 4) AND 11
14 | Combine | 12 OR 13
15 | Limit to english language | limit 14 to english language
16 | Limit to journals (excludes dissertations, etc. from PsycINFO) | limit 15 to all journals
17 | Limit by publication type | 16 NOT (book/ OR edited book OR case report/ OR case reports/ OR comment/ OR conference abstract/ OR conference paper/ OR conference review/ OR editorial/ OR letter/ OR news/ OR note/ OR proceeding/ OR (book OR edited book OR case report OR case reports OR comment OR conference abstract OR conference paper OR conference review OR editorial OR letter OR news OR note OR proceeding).pt. OR (“comment/reply” OR editorial OR letter OR review-book).dt.)
18 | Limit by publication date | Limit 17 to yr=“1990-Current”
19 | Limit to Adults in MEDLINE and EMBASE | 18 AND (adolescent/ OR child/ OR infant/ OR (adolescen^*^ OR juvenile^*^ OR teen^*^ OR young^*^ OR youth^*^).ti.)
20 | Limit to Adults in MEDLINE and EMBASE | 18 AND (Exp adult/ OR adult.ti.)
21 | Limit to Adults in MEDLINE and EMBASE | 19 NOT 20
22 | Limit to Adults in MEDLINE and EMBASE | 18 NOT 21
23 | | 22 use EMEZ
24 | | 22 use MESD
25 | | 23 OR 24
26 | Limit to Adults in PsycINFO using Empirical Population Limits | Limit 25 to (childhood <birth to 12 years> or adolescence <13 to 17 years>)
27 | Limit to Adults in PsycINFO using Empirical Population Limits | Limit 25 to adulthood <18+ years>
28 | Limit to Adults in PsycINFO using Empirical Population Limits | 26 NOT 27
29 | Limit to Adults in PsycINFO using Empirical Population Limits | 25 NOT 28
30 | Limit to Adults in PsycINFO using Empirical Population Limits | 29 use PSYF
31 | Total Adult studies sets | 25 OR 30
32 | Limit to studies performed in the United States, Canada, the United Kingdom, Australia, and New Zealand | 31 AND (exp africa/ OR exp asia/ OR exp central america/ OR exp eastern hemisphere/ OR exp europe/ OR exp latin america/ OR mexico/ OR exp south america/ OR exp south and central america/ OR (china OR finland OR france OR germany OR india OR iran OR ireland OR Italy OR japan OR malaysia OR mexico OR portugal OR singapore OR spain OR sweden OR taiwan OR thailand OR turkey).ti,in.)
33 | Limit to studies performed in the United States, Canada, the United Kingdom, Australia, and New Zealand | 31 AND (exp united states/ OR exp canada/ OR exp australasia/ OR exp australia/ and new zealand/ OR exp great britain/ OR exp united kingdom/ OR (america^*^ OR united states OR US OR USA OR canada^*^ OR australia OR new zealand OR england OR great britain OR united kingdom OR UK OR wales OR scotland).ti,in.)
34 | Limit to studies performed in the United States, Canada, the United Kingdom, Australia, and New Zealand | 32 NOT 33
35 | Limit to studies performed in the United States, Canada, the United Kingdom, Australia, and New Zealand | 31 NOT 34
36 | Eliminate overlap | Remove duplicates from 35 *

* Note that weeding for desired study types will be done by hand rather than with search limits

### Additional Conventions

#### PubMed

[tiab]: limit to title or abstract

#### Cochrane Library

Menu-driven

#### ProQuest Criminal Justice

^*^: truncation character (wildcard)
NEAR/n: search terms within a specified number (n) of words from each other in any order
[SU]: ProQuest subject heading
[TI]: limit to title
[AB]: limit to abstract
[STYPE]: source type (i.e., scholarly journal)

#### NCJRS

Menu-driven, thesaurus selections also available