# Abbreviations and Acronyms

ACT: Assertive community treatment
AHRQ: Agency for Healthcare Research and Quality
ANOVA: Analysis of variance
BDI: Beck Depression Inventory
BPRS: Brief Psychiatric Rating Scale
BSI: Brief Symptom Inventory
CBT: Cognitive behavior therapy
CI: Confidence interval
CJ: Criminal justice
CTI: Critical time interventions
DBT: Dialectical behavior therapy
DOC: Department of Corrections
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, third edition, revised
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, fourth edition
EPC: Evidence-based Practice Center
FACT: Forensic assertive community treatment
HRSD: Hamilton Rating Scale for Depression
ICD-10: International Statistical Classification of Diseases and Related Health Problems, 10th Revision
ICM: Intensive case management
IDDT: Integrated dual diagnosis treatment
IDDT: Integrated dual disorder treatment
IOP: Intensive outpatient program
IPT: Interpersonal therapy
KQ: Key question
LoC: Locus of Control
MAOI: Monoamine oxidase inhibitor
MH: Mental health
MICA: Mentally ill chemical abuser
MIOCTP: Mentally Ill Offender Community Transition Program
MTC: Modified therapeutic community
MVQ: Maudsley Violence Questionnaire
N: Number
NCJRS: National Criminal Justice Reference Service
NOS: Not otherwise specified
NOSIE: Nurses’ Observational Scale for Inpatient Evaluation
NR: Not reported
OR: Odds ratio
PSS: Posttraumatic Symptom Scale
pts.: Patients
R&R: Reasoning and Rehabilitation
RCT: Randomized controlled trial
RICCT: Reentry Intensive Care Coordination Team
SAMHSA: Substance Abuse and Mental Health Services Administration
SD: Standard deviation
SDAS: Social Dysfunction and Aggression Scale
SMD: Standardized mean difference
SMI: Serious mental illness
SOE: Strength of evidence
SPSI: Social Problem Solving Inventory
SSRI: Selective serotonin-reuptake inhibitor
TAU: Treatment as usual
TCA: Tricyclic antidepressant
TEP: Technical Expert Panel