# References

1 Bousquet J, Knani J, Hejjaoui A, et al. Heterogeneity of atopy. I. Clinical and immunologic characteristics of patients allergic to cypress pollen. Allergy. Apr. 1993;48(3):183-8. [pmid: 8506986].
2 Orban N, Saleh H, Durham S. Allergic and non-allergic rhinitis. Adkinson N, Bochner B, Busse W, Holgate S, Lemanske R, Simons F, editors. Middleton's Allergy: Principles and Practice. 7th ed. New York. Mosby. 2008.
3 Wallace DV, Dykewicz MS, Bernstein DI, et al. The diagnosis and management of rhinitis: an updated practice parameter. J Allergy Clin Immunol. Aug. 2008;122(2 Suppl):S1-84. [pmid: 18662584].
4 Plaut M, Valentine MD. Clinical practice. Allergic rhinitis. N Engl J Med. 2005;353(18):1934-44. [pmid: 16267324].
5 Gross GN. What are the Primary Clinical Symptoms of Rhinitis and What Causes Them?. Immunol Allergy Clin North Am. Aug. 2011;31(3):469-80. [pmid: 21737038].
6 Bousquet J, Van Cauwenberge P, Khaltaev N. Allergic rhinitis and its impact on asthma. J Allergy Clin Immunol. Nov. 2001;108(5 Suppl):S147-334. [pmid: 11707753].
7 Bauchau V, Durham SR. Epidemiological characterization of the intermittent and persistent types of allergic rhinitis. Allergy. Mar. 2005;60(3):350-3. [pmid: 15679721].
8 Skoner DP. Allergic rhinitis: definition, epidemiology, pathophysiology, detection, and diagnosis. J Allergy Clin Immunol. Jul. 2001;108(1 Suppl):S2-8. [pmid: 11449200].
9 Meltzer EO. The prevalence and medical and economic impact of allergic rhinitis in the United States. J Allergy Clin Immunol. Jun. 1997;99(6 Pt 2):S805-28. [pmid: 9215265].
10 Pleis J, Ward B, Lucas J. Summary health statistics for U.S. adults: National Health Interview Survey, 2009. National Center for Health Statistics. Vital Health Stat. 2010;10(249). [pmid: 21905346].
11 Bloom B, Cohen R, Freeman G. Summary health statistics for U.S. children: National Health Interview Survey, 2009. National Center for Health Statistics. Vital Health Stat. 2010;10(247).
12 Laforest L, Bousquet J, Pietri G, et al. Quality of life during pollen season in patients with seasonal allergic rhinitis with or without asthma. Int Arch Allergy Immunol. Mar. 2005;136(3):281-6. [pmid: 15722638].
13 Majani G, Baiardini I, Giardini A, et al. Health-related quality of life assessment in young adults with seasonal allergic rhinitis. Allergy. Apr. 2001;56(4):313-7. [pmid: 11284798].
14 Scadding GK, Richards DH, Price MJ. Patient and physician perspectives on the impact and management of perennial and seasonal allergic rhinitis. Clin Otolaryngol Allied Sci. 2000;25(6):551-7. [pmid: 11122298].
15 McNicholas WT, Tarlo S, Cole P, et al. Obstructive apneas during sleep in patients with seasonal allergic rhinitis. Am Rev Respir Dis. Oct. 1982;126(4):625-8. [pmid: 7125355].
16 Stuck BA, Czajkowski J, Hagner AE, et al. Changes in daytime sleepiness, quality of life, and objective sleep patterns in seasonal allergic rhinitis: a controlled clinical trial. J Allergy Clin Immunol. Apr. 2004;113(4):663-8. [pmid: 15100670].
17 Marshall PS, O'Hara C, Steinberg P. Effects of seasonal allergic rhinitis on selected cognitive abilities. Ann Allergy Asthma Immunol. Apr. 2000;84(4):403-10. [pmid: 10795648].
18 Juniper EF, Guyatt GH. Development and testing of a new measure of health status for clinical trials in rhinoconjunctivitis. Clin Exp Allergy. Jan. 1991;21(1):77-83. [pmid: 2021881].
19 Vuurman EF, van Veggel LM, Uiterwijk MM, et al. Seasonal allergic rhinitis and antihistamine effects on children's learning. Ann Allergy. Aug. 1993;71(2):121-6. [pmid: 8346863].
20 Walker S, Khan-Wasti S, Fletcher M, et al. Seasonal allergic rhinitis is associated with a detrimental effect on examination performance in United Kingdom teenagers: case-control study. J Allergy Clin Immunol. 2007;120(2):381-7. [pmid: 17560637].
21 Szeinbach SL, Seoane-Vazquez EC, Beyer A, et al. The impact of allergic rhinitis on work productivity. Prim Care Respir J. 2007. Apr. 2007;16(2):98-105. [pmid: 17404676].
22 Dykewicz MS, Hamilos DL. Rhinitis and sinusitis. J Allergy Clin Immunol. Feb. 2010;125(2 Suppl 2):S103-15. [pmid: 20176255].
23 Rosenwasser LJ. Current understanding of the pathophysiology of allergic rhinitis. Immunol Allergy Clin North Am. Aug. 2011;31(3):433-9. [pmid: 21737035].
24 Togias A. Unique mechanistic features of allergic rhinitis. J Allergy Clin Immunol. Jun. 2000;105(6 Pt 2):S599-604. [pmid: 10856164].
25 Mizuguchi H, Kitamura Y, Kondo Y, et al. Preseasonal prophylactic treatment with antihistamines suppresses nasal symptoms and expression of histamine H receptor mRNA in the nasal mucosa of patients with pollinosis. Methods Find Exp Clin Pharmacol. 2010;32(10):745-8. [pmid: 21225011].
26 Church MK, Maurer M, Simons FE, et al. Risk of first-generation H(1)-antihistamines: a GA(2)LEN position paper. Allergy. Apr. 2010;65(4):459-66. [pmid: 20146728].
27 Hoyte FC, Katial RK. Antihistamine therapy in allergic rhinitis. Immunol Allergy Clin North Am. Aug. 2011;31(3):509-43. [pmid: 21737041].
28 Brozek JL, Bousquet J, Baena-Cagnani CE, et al. Allergic Rhinitis and its Impact on Asthma (ARIA) guidelines: 2010 revision. J Allergy Clin Immunol. Sep. 2010;126(3):466-76. [pmid: 20816182].
29 Yanez A, Rodrigo GJ. Intranasal corticosteroids versus topical H1 receptor antagonists for the treatment of allergic rhinitis: a systematic review with meta-analysis. Ann Allergy Asthma Immunol. 2002;89(5):479-84. [pmid: 12452206].
30 Kaliner MA, Berger WE, Ratner PH, et al. The efficacy of intranasal antihistamines in the treatment of allergic rhinitis. Ann Allergy Asthma Immunol. 2011;106(2 Suppl):S6-S11. [pmid: 21277531].
31 Kushnir NM. The Role of Decongestants, Cromolyn, Guafenesin, Saline Washes, Capsaicin, Leukotriene Antagonists, and Other Treatments on Rhinitis. Immunol Allergy Clin North Am. Aug. 2011;31(3):601-17. [pmid: 21737044].
32 Institute for Clinical Systems Improvement. Health Care Guideline: Diagnosis and Treatment of Respiratory Illness in Children and Adults. 3rd ed. January. 2011.
33 Boehringer Ingelheim. Atrovent® (ipratropium bromide) nasal spray 0.06% prescribing information. October. 2011.
34 Kumar R, Kumar D, Parakh A. Fluticasone furoate: A new intranasal corticosteroid. Journal of Postgraduate Medicine. January-March. 2012;58(1):79-83. [pmid: 22387656].
35 Mattke S, Martorell F, Hong SY, et al. Anti-inflammatory medication adherence and cost and utilization of asthma care in a commercially insured population. J Asthma. Apr. 2010;47(3):323-9. [pmid: 20394518].
36 Harvey R, Hannan SA, Badia L, et al. Nasal saline irrigations for the symptoms of chronic rhinosinusitis. Cochrane Database Syst Rev. 2007;(3):CD006394. [pmid: 17636843].
37 Price D, Bond C, Bouchard J, et al. International Primary Care Respiratory Group (IPCRG) Guidelines: management of allergic rhinitis. Prim Care Respir J. 2006;15(1):58-70. [pmid: 16701759].
38 Scadding GK, Durham SR, Mirakian R, et al. BSACI guidelines for the management of allergic and non-allergic rhinitis. Clin Exp Allergy. Jan. 2008;38(1):19-42. [pmid: 18081563].
39 van Cauwenberge P, Bachert C, Passalacqua G, et al. Consensus statement on the treatment of allergic rhinitis. European Academy of Allergology and Clinical Immunology. Allergy. 2000;55(2):116-34. [pmid: 10726726].
40 Siow JK, Alshaikh NA, Balakrishnan A, et al. Ministry of Health clinical practice guidelines: Management of Rhinosinusitis and Allergic Rhinitis. Singapore Med J. 2010;51(3):190-7. [pmid: 20428739].
41 Benninger M, Farrar JR, Blaiss M, et al. Evaluating approved medications to treat allergic rhinitis in the United States: an evidence-based review of efficacy for nasal symptoms by class. Ann Allergy Asthma Immunol. 2010;104(1):13-29. [pmid: 20143641].
42 Nasser M, Fedorowicz Z, Aljufairi H, et al. Antihistamines used in addition to topical nasal steroids for intermittent and persistent allergic rhinitis in children. Cochrane Database Syst Rev. 2010;(7):CD006989. [pmid: 20614452].
43 Al Sayyad JJ, Fedorowicz Z, Alhashimi D, et al. Topical nasal steroids for intermittent and persistent allergic rhinitis in children. Cochrane Database Syst Rev. 2007;(1):CD003163. [pmid: 17253485].
44 Nasal Corticosteroids: Update 1 Final Report. Oregon Health & Science University, Center for Evidence-Based Policy. Drug Effectiveness Review Project. October. 1. 2008. http://derp.ohsu.edu/about/final-document-display.cfm.
45 Newer Antihistamines: Update 2 Final Report. Oregon Health & Science University, Center for Evidence-Based Policy. Drug Effectiveness Review Project. May. 1. 2010. http://derp.ohsu.edu/about/final-document-display.cfm.
46 McCrory DC, Williams JW, Dolor RJ, et al. Management of Allergic Rhinitis in the Working-Age Population. Evidence Report/Technology Assessment No. 67. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-17-0014.) AHRQ Publication No. 03-E015. Rockville, MD. Agency for Healthcare Research and Quality. March. 2003.
47 Long A, McFadden C, DeVine D, et al. Management of Allergic and Nonallergic Rhinitis. Evidence Report/Technology Assessment No. 54. (Prepared by the New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019.) AHRQ Publication No, 02-E024. Rockville, MD. Agency for Healthcare Research and Quality. May. 2002.
48 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. www.effectivehealthcare.ahrq.gov.
49 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
50 Guidance for Industry Allergic Rhinitis: Clinical Development Programs for Drug Products. Rockville, MD. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Center for Biologics Evaluation and Research, Center for Devices and Radiological Health. 2000.
51 White CM, Ip S, McPheeter M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. September. 2009. Rockville, MD. http://www.effectivehealthcare.ahrq.gov/ehc/products/123/329/SystematicReviewsReplaceDeNovo.pdf.
52 EndNote. XV ed. Thomson Reuters. 2011.
53 DistillerSR. Ottawa, Ontario. Evidence Partners Incorporated. 2010.
54 Office Excel 2007. 12 ed. Redmond, WA. Microsoft Corporation. 2007.
55 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
56 Stokes JR, Romero FA Jr., Allan RJ, et al. The effects of an H3 receptor antagonist (PF-03654746) with fexofenadine on reducing allergic rhinitis symptoms. Journal of Allergy & Clinical Immunology. Feb. 2012;129(2):409-12. 12.e1. 2. [pmid: 22196768].
57 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
58 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
59 Review Manager (RevMan). 5.1 ed. Copenhagen. The Nordic Cochrane Centre: The Cochrane Collaboration. 2011.
60 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. L. Erlbaum Associates. 1988.
61 Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0 ed. www.cochrane-handbook.org [updated March 2011].
62 Barnes ML, Ward JH, Fardon TC, et al. Effects of levocetirizine as add-on therapy to fluticasone in seasonal allergic rhinitis. Clin Exp Allergy. May. 2006;36(5):676-84. [pmid: 16650054].
63 Chivato T, Valovirta E, Dahl R, et al. Allergy, living and learning: Diagnosis and treatment of allergic respiratory diseases in Europe. Journal of Investigational Allergology and Clinical Immunology. 2012;22(3):168-79. [pmid: 22697006].
64 Guidance for Industry Patient-Reported Outcome Measures: Use in Medical Product Development to Support Labeling Claims. Rockville, MD. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research, Center for Biologics Evaluation and Research, Center for Devices and Radiological Health. 2009.
65 Mohar D, Desai S, Huang H, et al. An analysis of quality of life in subjects 18-64 years of age with seasonal allergic rhinitis following treatment with ciclesonide aqueous nasal spray. Journal of Allergy and Clinical Immunology. Conference: 2011 American Academy of Allergy, Asthma and Immunology, AAAAI Annual Meeting. San Francisco, CA United States. Conference Start: 20110318 Conference End: 20110322. 2011;127(2 Suppl 1):AB201.
66 Juniper EF, Thompson AK, Ferrie PJ, et al. Development and validation of the mini Rhinoconjunctivitis Quality of Life Questionnaire. Clin Exp Allergy. Jan. 2000;30(1):132-40. [pmid: 10606940].
67 Juniper EF, Rohrbaugh T, Meltzer EO. A questionnaire to measure quality of life in adults with nocturnal allergic rhinoconjunctivitis. J Allergy Clin Immunol. Mar. 2003;111(3):484-90. [pmid: 12642826].
68 Santanello NC, Zhang J, Seidenberg B, et al. What are minimal important changes for asthma measures in a clinical trial?. Eur Respir J. Jul. 1999;14(1):23-7. [pmid: 10489824].
69 Tepper RS, Wise RS, Covar R, et al. Asthma outcomes: pulmonary physiology. J Allergy Clin Immunol. Mar. 2012;129(3 Suppl):S65-87. [pmid: 22386510].
70 Scientific Advisory Committee on Respiratory and Allergy Therapies (SAC-RAT). 2008. http://www.hc-sc.gc.ca/dhp-mps/prodpharma/activit/sci-com/resp_allerg/sacrat_rop_ccstrta_crd_2008-12-09-eng.php.
71 Krishnan JA, Lemanske RF Jr., Canino GJ, et al. Asthma outcomes: symptoms. J Allergy Clin Immunol. Mar. 2012;129(3 Suppl):S124-35. [pmid: 22386505].
72 Barnes ML, Vaidyanathan PA, Williamson PA, et al. The minimal clinically important difference in allergic rhinitis. Clin Exp Allergy. May. 2010;36(5):676-84. [pmid: 16650054].
73 Bousquet PJ, Combescure C, Klossek JM, et al. Change in visual analog scale score in a pragmatic randomized cluster trial of allergic rhinitis. J Allergy Clin Immunol. Jun. 2009;123(6):1349-54. [pmid: 19368963].
74 Toskala EM, Krouse JH, Naclerio RM, et al. Facts and fictions about non-allergic rhinitis. Otolaryngology - Head and Neck Surgery. August. 2011;145:36.
75 Malling HJ. Criteria for clinical efficacy--readout and monitoring of clinical studies. Arb Paul Ehrlich Inst Bundesamt Sera Impfstoffe Frankf A M. 2003;(94):119-23. discussion 23-5. [pmid: 15119028].
76 Canonica GW, Baena-Cagnani CE, Bousquet J, et al. Recommendations for standardization of clinical trials with Allergen Specific Immunotherapy for respiratory allergy. A statement of a World Allergy Organization (WAO) taskforce. Allergy. Mar. 2007;62(3):317-24. [pmid: 17298350].
77 Wilson AM, O'Byrne PM, Parameswaran K. Leukotriene receptor antagonists for allergic rhinitis: a systematic review and meta-analysis. Am J Med. 2004. Mar. 1. 2004;116(5):338-44. [pmid: 14984820].
78 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. July. 2009. Rockville, MD. http://www.effectivehealthcare.ahrq.gov/ehc/products/60/318/2009_0805_grading.pdf.
79 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
80 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies when Comparing Medical Interventions. January. 2011. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 11-EHC019-EF. http://www.effectivehealthcare.ahrq.gov/tasks/sites/ehc/assets/File/Methods_Guide_Atkins.pdf.
81 Dockhorn RJ, Bergner A, Connell JT, et al. Safety and efficacy of loratadine (Sch-29851): a new non-sedating antihistamine in seasonal allergic rhinitis. Ann Allergy. 1987;58(6):407-11. [pmid: 2954497].
82 Harvey RP, Comer C, Sanders B, et al. Model for outcomes assessment of antihistamine use for seasonal allergic rhinitis. J Allergy Clin Immunol. 1996;97(6):1233-41. [pmid: 8648018].
83 Kemp JP, Bahna SL, Chervinsky P, et al. A Comparison of Loratadine, a New Nonsedating Antihistamine, with Clemastine and Placebo in Patients with Fall Seasonal Allergic Rhinitis. American Journal of Rhinology. 1987;1(3):151-4.
84 Berger WE, White MV. Efficacy of azelastine nasal spray in patients with an unsatisfactory response to loratadine. Ann Allergy Asthma Immunol. Aug. 2003;91(2):205-11. [pmid: 12952117].
85 Berger W, Hampel F Jr., Bernstein J, et al. Impact of azelastine nasal spray on symptoms and quality of life compared with cetirizine oral tablets in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. Sep. 2006;97(3):375-81. [pmid: 17042145].
86 Charpin D, Godard P, Garay RP, et al. A multicenter clinical study of the efficacy and tolerability of azelastine nasal spray in the treatment of seasonal allergic rhinitis: a comparison with oral cetirizine. Eur Arch Otorhinolaryngol. 1995;252(8):455-8. [pmid: 8719584].
87 Corren J, Storms W, Bernstein J, et al. Effectiveness of azelastine nasal spray compared with oral cetirizine in patients with seasonal allergic rhinitis. Clin Ther. 2005;27(5):543-53. [pmid: 15978303].
88 Gambardella R. A comparison of the efficacy of azelastine nasal spray and loratidine tablets in the treatment of seasonal allergic rhinitis. J Int Med Res. 1993;21(5):268-75. [pmid: 7906659].
89 Andrews CP, Martin BG, Jacobs RL, et al. Fluticasone furoate nasal spray is more effective than fexofenadine for nighttime symptoms of seasonal allergy. Allergy Asthma Proc. Mar-Apr. 2009;30(2):128-38. [pmid: 19463203].
90 Anolik R. Clinical benefits of combination treatment with mometasone furoate nasal spray and loratadine vs monotherapy with mometasone furoate in the treatment of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. Mar. 2008;100(3):264-71. [pmid: 18426147].
91 Bernstein DI, Levy AL, Hampel FC, et al. Treatment with intranasal fluticasone propionate significantly improves ocular symptoms in patients with seasonal allergic rhinitis. Clin Exp Allergy. Jun. 2004;34(6):952-7. [pmid: 15196285].
92 Condemi J, Schulz R, Lim J. Triamcinolone acetonide aqueous nasal spray versus loratadine in seasonal allergic rhinitis: efficacy and quality of life. Ann Allergy Asthma Immunol. 2000;84(5):533-8. [pmid: 10831008].
93 Gawchik SM, Lim J. Comparison of intranasal triamcinolone acetonide with oral loratadine in the treatment of seasonal ragweed-induced allergic rhinitis. Am J Manag Care. 1997;3(7):1052-8. [pmid: 10173369].
94 Gehanno P, Desfougeres JL. Fluticasone propionate aqueous nasal spray compared with oral loratadine in patients with seasonal allergic rhinitis. Allergy. Apr. 1997;52(4):445-50. [pmid: 9188929].
95 Jordana G, Dolovich J, Briscoe MP, et al. Intranasal fluticasone propionate versus loratadine in the treatment of adolescent patients with seasonal allergic rhinitis. J Allergy Clin Immunol. Feb. 1996;97(2):588-95. [pmid: 8621843].
96 Kaszuba SM, Baroody FM, deTineo M, et al. Superiority of an intranasal corticosteroid compared with an oral antihistamine in the as-needed treatment of seasonal allergic rhinitis. Arch Intern Med. 2001;161(21):2581-7. [pmid: 11718589].
97 Lu S, Malice MP, Dass SB, et al. Clinical studies of combination montelukast and loratadine in patients with seasonal allergic rhinitis. J Asthma. 2009;46(9):878-83. [pmid: 19905912].
98 Ratner PH, van Bavel JH, Martin BG, et al. A comparison of the efficacy of fluticasone propionate aqueous nasal spray and loratadine, alone and in combination, for the treatment of seasonal allergic rhinitis. J Fam Pract. 1998;47(2):118-25. [pmid: 9722799].
99 Schoenwetter W, Lim J. Comparison of intranasal triamcinolone acetonide with oral loratadine for the treatment of patients with seasonal allergic rhinitis. Clin Ther. 1995;17(3):479-92. [pmid: 7585852].
100 Vervloet D, Charpin D, Desfougeres JL. Intranasal fluticasone once daily compared with once-daily cetirizine in the treatment of seasonal allergic rhinitis. Results of a multicentre, double-blind study. Clinical Drug Investigation. 1997;13(6):291-8.
101 Bronsky E, Boggs P, Findlay S, et al. Comparative efficacy and safety of a once-daily loratadine-pseudoephedrine combination versus its components alone and placebo in the management of seasonal allergic rhinitis. J Allergy Clin Immunol. Aug. 1995;96(2):139-47. [pmid: 7636050].
102 Chervinsky P, Nayak A, Rooklin A, et al. Efficacy and safety of desloratadine/pseudoephedrine tablet, 2.5/120 mg two times a day, versus individual components in the treatment of patients with seasonal allergic rhinitis. Allergy Asthma Proc. 2005;26(5):391-6. [pmid: 16450574].
103 Grosclaude M, Mees K, Pinelli ME, et al. Cetirizine and pseudoephedrine retard, given alone or in combination, in patients with seasonal allergic rhinitis. Rhinology. 1997;35(2):67-73. [pmid: 9299654].
104 Grubbe RE, Lumry WR, Anolik R. Efficacy and safety of desloratadine/pseudoephedrine combination vs its components in seasonal allergic rhinitis. J Investig Allergol Clin Immunol. 2009;19(2):117-24. [pmid: 19476015].
105 Pleskow W, Grubbe R, Weiss S, et al. Efficacy and safety of an extended-release formulation of desloratadine and pseudoephedrine vs the individual components in the treatment of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2005;94(3):348-54. [pmid: 15801245].
106 Schenkel E, Corren J, Murray JJ. Efficacy of once-daily desloratadine/pseudoephedrine for relief of nasal congestion. Allergy Asthma Proc. 2002;23(5):325-30. [pmid: 12476542].
107 Sussman GL, Mason J, Compton D, et al. The efficacy and safety of fexofenadine HCl and pseudoephedrine, alone and in combination, in seasonal allergic rhinitis. J Allergy Clin Immunol. 1999;104(1):100-6. [pmid: 10400846].
108 Baena-Cagnani CE, Berger WE, DuBuske LM, et al. Comparative effects of desloratadine versus montelukast on asthma symptoms and use of beta 2-agonists in patients with seasonal allergic rhinitis and asthma. Int Arch Allergy Immunol. Apr. 2003;130(4):307-13. [pmid: 12740532].
109 Lombardo G, Quattrocchi P, Lombardo GR, et al. Concomitant levocetirizine and montelukast in the treatment of seasonal allergic rhinitis: Influence on clinical symptoms. Italian Journal of Allergy and Clinical Immunology. 2006;16(2):63-8.
110 Meltzer EO, Malmstrom K, Lu S, et al. Concomitant montelukast and loratadine as treatment for seasonal allergic rhinitis: a randomized, placebo-controlled clinical trial. J Allergy Clin Immunol. 2000;105(5):917-22. [pmid: 10808172].
111 Nayak AS, Philip G, Lu S, et al. Efficacy and tolerability of montelukast alone or in combination with loratadine in seasonal allergic rhinitis: a multicenter, randomized, double-blind, placebo-controlled trial performed in the fall. Ann Allergy Asthma Immunol. 2002;88(6):592-600. [pmid: 12086367].
112 Philip G, Malmstrom K, Hampel FC, et al. Montelukast for treating seasonal allergic rhinitis: a randomized, double-blind, placebo-controlled trial performed in the spring. Clin Exp Allergy. 2002;32(7):1020-8. [pmid: 12100048].
113 van Adelsberg J, Philip G, Pedinoff AJ, et al. Montelukast improves symptoms of seasonal allergic rhinitis over a 4-week treatment period. Allergy. 2003;58(12):1268-76. [pmid: 14616102].
114 van Adelsberg J, Philip G, LaForce CF, et al. Randomized controlled trial evaluating the clinical benefit of montelukast for treating spring seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2003;90(2):214-22. [pmid: 12602669].
115 Carr W, Bernstein J, Lieberman P, et al. A novel intranasal therapy of azelastine with fluticasone for the treatment of allergic rhinitis. Journal of Allergy & Clinical Immunology. 2012. Mar. 12. [pmid: 22418065].
116 Ghimire A, Das BP, Mishra SC. Comparative efficacy of steroid nasal spray versus antihistamine nasal spray in allergic rhinitis. Nepal Med Coll J. Mar. 2007;9(1):17-21. [pmid: 17593672].
117 Hampel FC, Ratner PH, Van Bavel J, et al. Double-blind, placebo-controlled study of azelastine and fluticasone in a single nasal spray delivery device. Ann Allergy Asthma Immunol. Aug. 2010;105(2):168-73. [pmid: 20674829].
118 Kaliner MA, Storms W, Tilles S, et al. Comparison of olopatadine 0.6% nasal spray versus fluticasone propionate 50 microg in the treatment of seasonal allergic rhinitis. Allergy Asthma Proc. May-Jun. 2009;30(3):255-62. [pmid: 19549426].
119 Newson-Smith G, Powell M, Baehre M, et al. A placebo controlled study comparing the efficacy of intranasal azelastine and beclomethasone in the treatment of seasonal allergic rhinitis. Eur Arch Otorhinolaryngol. 1997;254(5):236-41. [pmid: 9195148].
120 Pelucchi A, Chiapparino A, Mastropasqua B, et al. Effect of intranasal azelastine and beclomethasone dipropionate on nasal symptoms, nasal cytology, and bronchial responsiveness to methacholine in allergic rhinitis in response to grass pollens. J Allergy Clin Immunol. 1995;95(2):515-23. [pmid: 7852667].
121 Ratner PH, Hampel F, Van Bavel J, et al. Combination therapy with azelastine hydrochloride nasal spray and fluticasone propionate nasal spray in the treatment of patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. Jan. 2008;100(1):74-81. [pmid: 18254486].
122 Bjerrum P, Illum P. Treatment of seasonal allergic rhinitis with budesonide and disodium cromoglycate. A double-blind clinical comparison between budesonide and disodium cromoglycate. Allergy. Jan. 1985;40(1):65-9. [pmid: 3919604].
123 Bousquet J, Chanal I, Alquie MC, et al. Prevention of pollen rhinitis symptoms: comparison of fluticasone propionate aqueous nasal spray and disodium cromoglycate aqueous nasal spray. A multicenter, double-blind, double-dummy, parallel-group study. Allergy. Jul. 1993;48(5):327-33. [pmid: 8368459].
124 Lange B, Lukat KF, Rettig K, et al. Efficacy, cost-effectiveness, and tolerability of mometasone furoate, levocabastine, and disodium cromoglycate nasal sprays in the treatment of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2005;95(3):272-82. [pmid: 16200819].
125 Welsh PW, Stricker WE, Chu CP, et al. Efficacy of beclomethasone nasal solution, flunisolide, and cromolyn in relieving symptoms of ragweed allergy. Mayo Clin Proc. 1987;62(2):125-34. [pmid: 3100877].
126 Martin BG, Andrews CP, van Bavel JH, et al. Comparison of fluticasone propionate aqueous nasal spray and oral montelukast for the treatment of seasonal allergic rhinitis symptoms. Ann Allergy Asthma Immunol. 2006;96(6):851-7. [pmid: 16802774].
127 Nathan RA, Yancey SW, Waitkus-Edwards K, et al. Fluticasone propionate nasal spray is superior to montelukast for allergic rhinitis while neither affects overall asthma control. Chest. Oct. 2005;128(4):1910-20. [pmid: 16236835].
128 Pullerits T, Praks L, Ristioja V, et al. Comparison of a nasal glucocorticoid, antileukotriene, and a combination of antileukotriene and antihistamine in the treatment of seasonal allergic rhinitis. J Allergy Clin Immunol. 2002;109(6):949-55. [pmid: 12063523].
129 Ratner PH, Howland WC 3rd, Arastu R, et al. Fluticasone propionate aqueous nasal spray provided significantly greater improvement in daytime and nighttime nasal symptoms of seasonal allergic rhinitis compared with montelukast. Ann Allergy Asthma Immunol. 2003;90(5):536-42. [pmid: 12775135].
130 Wilson A, Dempsey OJ, Sims EJ, et al. Evaluation of treatment response in patients with seasonal allergic rhinitis using domiciliary nasal peak inspiratory flow. Clin Exp Allergy. 2000;30(6):833-8. [pmid: 10848901].
131 Benincasa C, Lloyd RS. Evaluation of fluticasone propionate aqueous nasal spray taken alone and in combination with cetirizine in the prophylactic treatment of seasonal allergic rhinitis. Drug Investigation. 1994;8(4):225-33.
132 Di Lorenzo G, Pacor ML, Pellitteri ME, et al. Randomized placebo-controlled trial comparing fluticasone aqueous nasal spray in mono-therapy, fluticasone plus cetirizine, fluticasone plus montelukast and cetirizine plus montelukast for seasonal allergic rhinitis. Clin Exp Allergy. 2004;34(2):259-67. [pmid: 14987306].
133 Boner AL, Miglioranzi P, Richelli C, et al. Efficacy and safety of loratadine suspension in the treatment of children with allergic rhinitis. Allergy. 1989. Aug. 1989;44(6):437-41. [pmid: 2572182].
134 Tinkelman DG, Kemp J, Mitchell DQ, et al. Treatment of seasonal allergic rhinitis in children with cetirizine or chlorpheniramine: A multicenter study. Pediatric Asthma, Allergy and Immunology. 1996;10(1):9-17.
135 Fuhlbrigge A, Peden D, Apter AJ, et al. Asthma outcomes: exacerbations. J Allergy Clin Immunol. Mar. 2012;129(3 Suppl):S34-48. [pmid: 22386508].
136 Morrow-Brown H, Jackson FA, Pover GM. A comparison of beclomethasone dipropionate aqueous nasal spray and sodium cromoglycate nasal spray in the management of seasonal allergic rhinitis. Allergol Immunopathol (Madr). 1984;12(5):355-61. [pmid: 6441477].
137 Brown HM, Engler C, English JR. A comparative trial of flunisolide and sodium cromoglycate nasal sprays in the treatment of seasonal allergic rhinitis. Clin Allergy. 1981;11(2):169-73. [pmid: 6786796].
138 Izumi N, Mizuguchi H, Umehara H, et al. Analysis of disease-dependent sedative profiles of H(1)-antihistamines by large-scale surveillance using the visual analog scale. Methods Find Exp Clin Pharmacol. 2008;30(3):225-30. [pmid: 18597008].
139 Engstrom I, Oberger E, Blyckert A, et al. Disodium cromoglycate in the treatment of seasonal allergic rhinoconjunctivitis in children. Ann Allergy. 1971;29(10):505-9. [pmid: 4999756].
140 Can D, Tanac R, Demir E, et al. Is the usage of intranasal glucocorticosteroids alone in allergic rhinitis sufficient?. Allergy Asthma Proc. 2006;27(3):248-53. [pmid: 16913269].
141 Fisher WG. Comparison of budesonide and disodium cromoglycate for the treatment of seasonal allergic rhinitis in children. Ann Allergy. 1994;73(6):515-20. [pmid: 7998667].
142 Bender BG, McCormick DR, Milgrom H. Children's school performance is not impaired by short-term administration of diphenhydramine or loratadine. J Pediatr. 2001;138(5):656-60. [pmid: 11343039].
143 Martinati LC, Sette L, Chiocca E, et al. Effect of beclomethasone dipropionate nasal aerosol on serum markers of bone metabolism in children with seasonal allergic rhinitis. Clin Exp Allergy. 1993;23(12):986-91. [pmid: 10779290].
144 Daley-Yates P, Ambery C, Sweeney L, et al. The efficacy and tolerability of two novel H(1)/H(3) receptor antagonists in seasonal allergic rhinitis. International Archives of Allergy & Immunology. 2012;158(1):84-98. [pmid: 22212854].
145 Hodge LS, Tracy TS. Alterations in drug disposition during pregnancy: implications for drug therapy. Expert Opin Drug Metab Toxicol. Aug. 2007;3(4):557-71. [pmid: 17696806].
146 Howland WC, Amar NJ, Wheeler W, et al. Efficacy and safety of azelastine 015% nasal spray administered once daily in patients with allergy to Texas mountain cedar pollen. International Forum of Allergy & Rhinology. Jul-Aug. 2011;1(4):275-9. [pmid: 22287431].
147 Sheikh A, Singh Panesar S, Salvilla S, et al. Hay fever in adolescents and adults. Clinical Evidence. Nov. 18. 2009;11:509. [pmid: 21726475].
148 Topuz B, Ogmen GG. Montelukast as an adjuvant to mainstay therapies in patients with seasonal allergic rhinitis. Clin Exp Allergy. 2003. Jun. 2003;33(6):823-6. [pmid: 12801319].