# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, Peer Reviewers with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jan Brozek, M.D., Ph.D.
  Assistant Professor, Department of Clinical Epidemiology & Biostatistics
  McMaster University
  Hamilton, Ontario, Canada
- Doug Campos-Outcalt, M.D.
  Associate Chair, Department of Family and Community Medicine
  University of Arizona College of Medicine
  Phoenix, AZ
- Paul A. Greenberger, M.D.
  Professor of Medicine, Division of Allergy and Immunology
  Northwestern University Feinberg School of Medicine
  Chicago IL
- Dana Wallace, M.D.
  Assistant Clinical Professor
  Nova Southeastern University
  Davie, FL
- Chester Zeiss, M.D.
  Allergy & Immunology
  Northwestern Memorial Hospital
  Chicago, IL