# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Ian M. Bennett, M.D., Ph.D.
  Associate Professor of Family Medicine and Community Health
  University of Pennsylvania
  Philadelphia, PA
- Linda Cox, M.D.
  President, American Academy of Allergy, Asthma, and Immunology
  Fort Lauderdale, FL
- Leslie Grammer, M.D.
  Associate Chief for Clinical Affairs, Division of Allergy Immunology
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Brandon Jennings, Pharm.D.
  Assistant Professor of Pharmacotherapy
  University of Utah College of Pharmacy
  Salt Lake City, UT
- Robert C. Kern, M.D.
  Professor, Department of Otolaryngology-Head and Neck Surgery
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Thomas F. Koinis, M.D., FAAFP
  Duke Primary Care - OxfordDuke University Health System
  Oxford, NC
- Alkis Togias, M.D.
  Chief, Asthma and Airway Biology Section
  National Institute of Allergy and Infectious Diseases
  Bethesda, MD