# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought Key Informant input on priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Ian M. Bennett, M.D., Ph.D.
  Associate Professor of Family Medicine and Community Health
  University of Pennsylvania
  Philadelphia, PA
- Linda Cox, M.D.
  President, American Academy of Allergy, Asthma, and Immunology
  Fort Lauderdale, FL
- Mary Beth Erwin, R.Ph., M.P.H.
  Clinical Pharmacy Senior Manager
  Blue Cross Blue Shield of Massachusetts
  Attleboro, MA
- Leslie Grammer, M.D.
  Associate Chief for Clinical Affairs, Division of Allergy Immunology
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Brandon Jennings, Pharm.D.
  Assistant Professor of Pharmacotherapy
  University of Utah College of Pharmacy
  Salt Lake City, UT
- Carolyn Kercsmar, M.D.
  Professor, University of Cincinnati Department of Pediatrics
  Cincinnati Children's Hospital
  Cincinnati, OH
- Robert C. Kern, M.D.
  Professor, Department of Otolaryngology-Head and Neck Surgery
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Thomas F. Koinis, M.D., FAAFP
  Duke Primary Care - OxfordDuke University Health System
  Oxford, NC
- Arthur Levin, M.P.H.
  Director, Center for Medical Consumers
  New York, NY
- Caroline Moassessi
  Patient Advocate
  Northern Nevada Asthma & Allergy Parents Education Group (AAPE)
  Reno, NV
- Alkis Togias, M.D.
  Chief, Asthma and Airway Biology Section
  National Institute of Allergy and Infectious Diseases
  Bethesda, MD