# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S.; Jennifer Brock, M.P.H.; Lisa Garofalo, B.A.; Lisa Sarsany, M.A.; Vikrant Vats, Ph.D.; Kathleen Ziegler, Pharm.D. The authors would also like to thank Anju Peters, M.D., our clinical content expert, for valuable input and guidance.