# Discussion

## Key Findings and Strength of Evidence

This report reviews 59 randomized, controlled trials (RCTs) of treatments for seasonal allergic rhinitis (SAR) in adults and adolescents, in children younger than 12 years of age, and in pregnant women. In adults and adolescents, oral drug classes studied were selective and nonselective antihistamine, sympathomimetic decongestant, and leukotriene receptor antagonist; nasal drug classes were antihistamine, corticosteroid, and cromolyn. No RCTs or observational studies of intranasal anticholinergic or nasal saline spray were identified. In children, drug classes studied were oral selective and nonselective antihistamine. In this population, no RCTs or observational studies of nasal antihistamine, corticosteroid, or cromolyn; oral leukotriene receptor antagonist; or nasal saline spray were identified. No RCTs or observational studies of SAR treatments in pregnant women were identified.

## Key Question 1 Comparative Effectiveness of SAR Treatments in Adults and Adolescents 12 Years of Age or Older

### Overview of Results

Twenty-two treatment comparisons of interest were identified. We found studies that satisfied our inclusion criteria for 13 of these. Results for these comparisons are presented in Table 73 and discussed below. For most outcomes, evidence was insufficient to form any comparative effectiveness conclusion. In five comparisons, we found evidence for comparable effectiveness (equivalence) of treatments for at least one outcome (rows 5, 6, 8, 11, and 12 in Table 73), and we found evidence for superior effectiveness of one treatment over another for one outcome in each of two comparisons (row 5 and row 9 in Table 73).

Table 73 Summary of findings and strength of evidence for effectiveness in 13 treatment comparisons: Key Question 1–adults and adolescents

Comparison | Representation^a^ | Nasal Symptoms | Eye Symptoms | Asthma Symptoms | Quality of Life
1. Oral S-AH vs. Oral nS-AH | 40% vs. 18% | Insufficient | | | Insufficient
2. Oral S-AH vs. Nasal AH | 60% vs. azelastine (50%) | Insufficient | | | Insufficient
3. Oral S-AH vs. INCS | 60% vs. 62.5% | Insufficient | Insufficient | | Insufficient
4. Oral S-AH vs. Oral D | 80% vs. pseudoephedrine (50%) | Insufficient | Insufficient
5. Oral S-AH vs. LRA | 60% vs. montelukast (100%) | Equivalent: Moderate^b^ | Equivalent: Moderate^c^ | LRA: Moderate^d^ | Equivalent: Moderate^e^
6. INCS vs. Nasal AH | 25% vs. 100% | Equivalent: High^f^ | Equivalent: High^g^ | | Insufficient
7. INCS vs. Nasal C | 62.5% vs. cromolyn (100%) | Insufficient
8. INCS vs. LRA | 25% vs. montelukast (100%) | Equivalent: High^h^ | | Insufficient
9. Oral S-AH + INCS vs. Oral S-AH | 40% Oral S-AH, 25% INCS | Insufficient | Insufficient | | Oral S-AH + INCS: Low^e^
10. Oral S-AH + INCS vs. INCS | 60% Oral S-AH, 25% INCS | Insufficient | Insufficient | | Insufficient
11. INCS + Nasal AH vs. INCS | FP (12.5%), azelastine (50%) | Equivalent: High^f^ | Equivalent: High^g^ | | Insufficient
12. INCS + Nasal AH vs. Nasal AH | FP (12.5%), azelastine (50%) | Equivalent: High^f^ | Equivalent: High^g^ | | Insufficient
13. Oral S-AH + Oral D vs. Oral S-AH | 80% Oral S-AH, pseudoephedrine (50%) | Insufficient | Insufficient

AH = antihistamine; C = cromolyn; D = sympathomimetic decongestant; FP = fluticasone propionate; INCS = intranasal corticosteroid; LRA = leukotriene receptor antagonist; nS-AH = nonselective antihistamine; S-AH = selective antihistamine.

Entries indicate comparative efficacy conclusions supported by the evidence, or insufficient evidence to form a conclusion. Empty cells indicate outcomes that were not assessed.

Conclusions are indicated by Conclusion: Strength of evidence (SOE):

- “Equivalent” indicates sufficient evidence to support a conclusion of equivalence (comparable effectiveness) between compared treatments for the outcome indicated.
- “LRA” and “Oral S-AH + INCS” indicate sufficient evidence to support conclusions of superiority of these treatments over their respective comparators for the indicated outcomes.
- SOE is indicated by Low (low SOE), Moderate (moderate SOE), and High (high SOE).

“Insufficient” indicates insufficient evidence to form a conclusion.

- For the comparison of oral selective antihistamine to intranasal corticosteroid (row 3), evidence was insufficient to form conclusions of superiority or equivalence for nasal and eye symptoms.
- For all other outcomes, “Insufficient” indicates insufficient evidence for conclusions of superiority; equivalence was not assessed.

a Representation indicates the proportion of drugs in each class that were studied. For comparisons involving combination therapy (rows 9 through 13), the proportion of the drug class studied as monotherapy is the same as the proportion of that drug class studied in combination therapy. For example, in row 9, two of five oral selective antihistamines (40 percent) were studied as monotherapy, and the same two antihistamines were studied in combination therapy.

b Total Nasal Symptom Score at 2-4 weeks.

c Total Ocular Symptom Score (eye tearing, itching, redness, and puffiness) at 2-4 weeks.

d Rescue medication use at 2 and 4 weeks. For other asthma outcomes (symptoms and forced expired volume in 1 second [FEV_1_]), evidence was insufficient to form a comparative effectiveness conclusion.

e Rhinitis Quality of Life Questionnaire at 2-4 weeks.

f Congestion, rhinorrhea, sneezing, nasal itch and Total Nasal Symptom Score at 2 weeks.

g Total Ocular Symptom Score at 2 weeks.

h Congestion, rhinorrhea, sneezing, nasal itch and Total Nasal Symptom Score at 2 weeks.

When reviewing Table 73, it is important to keep in mind that the strength of evidence analysis only describes the evidence for each specific treatment comparison. That is, conclusions about equivalence or superiority can be made when two treatments are directly compared. In the absence of direct comparison, neither conclusion is supported. For example, for various nasal symptom outcomes, there was moderate strength evidence for comparable effectiveness (equivalence) of oral selective antihistamine and oral leukotriene receptor antagonist (row 5), and high strength evidence for the comparable effectiveness of intranasal corticosteroid and oral leukotriene receptor antagonist (row 8). This does not support a conclusion of equivalence of oral selective antihistamine and intranasal corticosteroid for nasal symptoms. As shown in row 3, direct evidence from the comparison of oral selective antihistamine to intranasal corticosteroid for the treatment of nasal symptoms was insufficient to form a conclusion about their comparative effectiveness. In contrast, high strength evidence suggests comparable effectiveness of intranasal corticosteroid plus nasal antihistamine combination therapy and each of its components for nasal and eye symptoms (rows 11 and 12). Direct evidence also suggests comparable effectiveness of intranasal corticosteroid and nasal antihistamine for these outcomes (row 6), suggesting comparable effectiveness of all three treatments.

It also is important to keep in mind that:

- Results presented in the summary table, indeed in the entire report, reflect the reporting of data in the literature. Data that were reported with insufficient detail to permit their inclusion in meta-analysis restricted the comparative effectiveness conclusions that could be drawn. Data reported with insufficient detail to assess their quality reduces the strength of the body of evidence. This was particularly evident in three-arm trials in which p-values for comparisons of interest for this review were not the primary comparisons in the trial. It may be that in some cases the reporting of the evidence, rather than the evidence itself, is insufficient to make any conclusion about the comparative effectiveness of two treatments. (See Limitations of the Evidence Base, below.)
- Seven of 13 treatment comparisons (54 percent) had poor representation (less than 50 percent) of at least one drug class compared. Although the Technical Expert Panel (TEP) was unaware of evidence suggesting differential effectiveness within a class, these seven comparisons may not adequately represent the classes of drugs compared, and conclusions are limited to the specific drugs studied. The seven comparisons are listed below with the proportion of drugs represented in each class indicated in parentheses.
  ○ Oral selective versus oral nonselective antihistamine (40 percent versus 25 percent)
  ○ Intranasal corticosteroid versus nasal antihistamine (25 percent versus 100 percent)
  ○ Intranasal corticosteroid versus oral leukotriene receptor antagonist (25 percent versus 100 percent)
  ○ Combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine (40 percent of oral selective antihistamines and 25 percent of intranasal corticosteroids)
  ○ Combination oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid (60 percent of oral selective antihistamines and 25 percent of intranasal corticosteroids)
  ○ Combination intranasal corticosteroid plus nasal antihistamine versus intranasal corticosteroid (12.5 percent of intranasal corticosteroids and 50 percent of nasal antihistamines)
  ○ Combination intranasal corticosteroid plus nasal antihistamine versus nasal antihistamine (12.5 percent of intranasal corticosteroids and 50 percent of nasal antihistamines)

For some drug classes, the impact of poor representation may be limited; for example, 25 percent of oral nonselective antihistamines were studied in two comparisons, but this class of drugs is used less often since the advent of newer treatments. Similarly, only one of two oral decongestants was studied (pseudoephedrine), the one that is most commonly used.

In four comparisons, intranasal corticosteroid alone or in combination was poorly represented: In two (versus nasal antihistamine and versus oral leukotriene receptor antagonist), only fluticasone propionate and budesonide were studied. In the other two (combination intranasal corticosteroid plus nasal antihistamine versus each component), only fluticasone propionate was studied. Comparative effectiveness conclusions therefore apply to the specific drugs in each comparison; how well they generalize to other drugs in the same class is uncertain.

Cells marked “Insufficient” indicate insufficient evidence to form a conclusion. As described in the Methods section, conclusions that could be drawn for any outcome depended on the nature of the evidence available:

- For outcomes that had minimal clinically important differences (MCIDs) and meta-analysis was done, conclusions of superiority, equivalence, or insufficient evidence could be made.
- For outcomes that had an MCID and meta-analysis was not done, only conclusions of superiority or insufficient evidence could be made.
- For outcomes with no MCID, only conclusions of superiority or insufficient evidence could be made regardless of whether meta-analysis was done.

Of 28 meta-analyses conducted, 26 supported equivalence conclusions. The other two meta-analyses assessed oral selective antihistamine in comparison to intranasal corticosteroid (row 3). In approximately half of the trials identified for this comparison, treatment effects for nasal and eye symptoms were not reported. Therefore, the evidence was imprecise and insufficient to support a comparative effectiveness conclusion of superiority or equivalence for these outcomes. All other “Insufficient” cells indicate insufficient evidence to support only superiority conclusions.

As shown in Table 73, we found:

- High strength evidence for comparable effectiveness (equivalence) of:
  ○ Combination intranasal corticosteroid plus nasal antihistamine, intranasal corticosteroid monotherapy, and nasal antihistamine monotherapy for nasal and eye symptoms at 2 weeks.
  ○ Intranasal corticosteroid and oral leukotriene receptor antagonist (montelukast) for nasal symptoms at 2 weeks.
- Moderate strength evidence for comparable effectiveness of oral selective antihistamine and oral leukotriene receptor antagonist for nasal and eye symptoms and for improved quality of life at 2-4 weeks.
- Moderate strength evidence for the use of oral leukotriene receptor antagonist over oral selective antihistamine for reduced asthma rescue medication use at 2-4 weeks.
- Low strength evidence for the use of combination oral selective antihistamine plus intranasal corticosteroid over oral selective antihistamine monotherapy for improved quality of life at 2-4 weeks.

### Sensitivity Analysis

These findings and strength of evidence ratings were directly impacted by our choice of the MCID for each outcome. In the absence of well-defined MCIDs for symptom outcomes, we selected an MCID of 30 percent maximum score based on our review of the literature and input from the TEP. In sensitivity analysis, we reduced this value by one third (i.e., to 20 percent maximum score) and found five comparisons affected. Of these five, one conclusion changed (#5 below).

- Oral selective antihistamine versus oral decongestant: eye symptoms at 2 weeks
  ○ Original conclusion: Insufficient evidence to support the use of one treatment over the other based on two good quality trials103, 107 (N=890) with low risk of bias and consistent but imprecise treatment effects favoring oral selective antihistamine.
  ○ Result of sensitivity analysis: One trial107 (n=436) reported a treatment effect of 25 percent maximum score. This trial107 represented 49 percent of patients reporting this outcome. Because approximately half of patients would still be in the trial103 with imprecise results, the body of evidence would remain imprecise.
- Intranasal corticosteroid versus nasal antihistamine: nasal congestion at 2 weeks
  ○ Original conclusion: High strength of evidence for comparable effectiveness (equivalence) of the treatments based on eight trials115-119, 121 (N=2443) with low risk of bias and consistent and precise results.
  ○ Result of sensitivity analysis: One poor quality trial116 (n=50) reported a treatment effect of 23 percent maximum score favoring intranasal corticosteroid. Because this trial represented 2 percent of patients reporting this outcome, its impact on the overall precision of the body of evidence was minimal, and the body of evidence would remain imprecise.
- Intranasal corticosteroid versus nasal cromolyn: rhinorrhea at 2 weeks
  ○ Original conclusion: Insufficient evidence to support the use of one treatment over the other based on one poor quality trial122 (n=43) with high risk of bias and an imprecise treatment effect favoring intranasal corticosteroid.
  ○ Result of sensitivity analysis: The treatment effect represented 20 percent of maximum score. If this were considered a precise result, the strength of evidence would remain insufficient to support the use of one treatment over the other due to the high risk of bias and unknown consistency of the body of evidence.
- Combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine monotherapy: total nasal symptom score (TNSS) at 2 weeks
  ○ Original conclusion: Insufficient evidence to support the use of one treatment over the other based on three trials90, 98, 130 (N=677) with high risk of bias and consistent but imprecise results.
  ○ Result of sensitivity analysis: One fair quality trial98 (n=300) reported a treatment effect of 22 percent maximum score. This trial98 represented 44 percent of patients reporting this outcome. Because the majority of patients would still be in the trials90, 130 with imprecise results, the body of evidence would remain imprecise.
- Combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine monotherapy: TNSS at 2 weeks
  ○ Original conclusion: Insufficient evidence to support the use of one treatment over the other based on one good quality trial101 (n=438) with low risk of bias and an imprecise treatment effect favoring combination therapy.
  ○ Result of sensitivity analysis: The treatment effect represented 20 percent of maximum score. If this were considered a precise result, the strength of evidence to support the use of combination oral selective antihistamine plus oral decongestant over oral selective antihistamine monotherapy would be moderate.

### Responder Analysis

To demonstrate clinically meaningful treatment effects, the preferred analysis is a responder analysis, in which the outcome of interest is the proportion of patients who reached a predefined minimum threshold of improvement. However, a well-defined MCID is required for a robust responder analysis, and most trials did not use this approach. In meta-analyses of three trials that compared combination intranasal corticosteroid plus nasal antihistamine to both intranasal corticosteroid and nasal antihistamine monotherapy (total N=3150), responder analyses were included.115 Response was defined as a 50 percent reduction from baseline TNSS on a 0-24 point scale. Resolution was defined as reduction in all individual nasal symptom scores to less than 1.0 on a 0-6 point scale. It is unclear how these thresholds were derived. For the comparison of combination therapy to nasal antihistamine monotherapy, a statistically significantly greater proportion of patients achieved both resolution (p<0.001) and response (p<0.001) with combination therapy. For the comparison of combination therapy to intranasal corticosteroid monotherapy, a statistically significantly greater proportion of patients achieved resolution with combination therapy (p=0.033), but the difference in the proportion of patients achieving response was not statistically significant (p=0.071). Correlation of these results with the results presented in the current report is limited by definitions of “response” and “resolution,” which did not include MCIDs. Because the published meta-analyses lacked details about the how the analyses were conducted, results could not be replicated. Therefore, these findings do not alter our conclusions of comparable effectiveness (equivalence) of these treatments for nasal symptom outcomes.

### Subgroups

We were limited in our ability to address identified subgroups of interest, that is, patients codiagnosed with asthma or allergic conjunctivitis. For asthma, only the two comparisons of oral leukotriene receptor antagonist (montelukast), to oral selective antihistamine and to intranasal corticosteroid, included asthma outcomes. In one of these, moderate strength evidence supported the superiority of montelukast over oral selective antihistamine for reduction in rescue medication use; for other asthma outcomes assessed in this comparison (asthma symptoms and forced expired volume in 1 second [FEV_1_]), evidence was insufficient to form conclusions. In the other comparison, evidence was insufficient to support either intranasal corticosteroid or montelukast for asthma outcomes (symptom-free days, albuterol-free days, morning and evening peak expired flow [PEF], and asthma exacerbations). Eye symptom outcomes were reported in ten treatment comparisons. Of these, conclusions of equivalence of the two treatments were made in four. For each of these comparisons, equivalence also was concluded for nasal symptoms (see Table 73).

We were limited in our ability to address differences in effectiveness between patients with mild symptoms and patients with moderate/severe symptoms. Most trials enrolled patients with moderate/severe baseline SAR symptoms. Those that included patients with mild severity did not report results separately for these patients. Three small trials122, 128, 130 (total N=81) reported mean baseline TNSS that were in the mild range. Two of these were rated poor quality122, 128 and favored intranasal corticosteroid over nasal cromolyn122 and over oral leukotriene receptor antagonist128 for nasal symptoms. The third130 (n=27) was a fair quality trial that favored combination oral selective antihistamine plus intranasal corticosteroid over oral selective antihistamine monotherapy for nasal symptoms. Treatment effects ranged from 2 percent to 20 percent of maximum score. The evidence is insufficient to suggest that mild nasal symptoms respond differently than moderate/severe symptoms to the specific treatments compared. However, this conclusion is preliminary until replicated by larger, higher quality trials.

### Duration of Treatment

Finally, six trials88, 120, 123, 125, 128, 131, 132 in four comparisons were longer than 4 weeks in duration. Each of the four comparisons is discussed below. Additionally:

- Because each of the four comparisons involved intranasal corticosteroid, outcomes at 2 weeks and after 2 weeks are compared.
- Two of four other comparisons that involved intranasal corticosteroid included trials of 2 and 4 weeks' duration. These outcomes also are reviewed below.
- The remaining two comparisons that involved intranasal corticosteroid (combination intranasal corticosteroid plus nasal antihistamine versus each component) included trials of 2 weeks' duration only. These trials are not discussed here.

Overall, the evidence is insufficient to suggest that comparative effectiveness at later time points up to 8 weeks differs from effectiveness at 2 to 4 weeks.

Comparisons that included trials longer than 4 weeks
- Intranasal corticosteroid versus nasal antihistamine: Two poor quality trials116, 120 (total N=80) favored nasal antihistamine for nasal symptoms at 3, 4, and 5 weeks. Treatment effects ranged from 8 to 17 percent of maximum score. At 2 weeks, high strength evidence supported comparable effectiveness (equivalence) of intranasal corticosteroid and nasal antihistamine for nasal symptoms.
- Intranasal corticosteroid versus nasal cromolyn: Three poor quality trials122-124 (total N=344) favored intranasal corticosteroid for nasal symptoms at 3 to 6 weeks. Treatment effects ranged from 5 to 16 percent of maximum score. One poor quality trial125 (n=90) favored intranasal corticosteroid for patient global assessment of symptoms (PGA) at 8 weeks. At 2 weeks, evidence was insufficient to support the use of one treatment over the other for either of these outcomes.
- Intranasal corticosteroid versus oral leukotriene receptor antagonist: Two poor quality trials127, 128 (total N=602) favored intranasal corticosteroid at 3 to 8 weeks for nasal symptoms. Treatment effects ranged from 4 to 9 percent of maximum score. At 2 weeks, high strength evidence supported comparable effectiveness of intranasal corticosteroid and montelukast for nasal symptoms.
- Combination oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid: Evidence was insufficient to support the use of one treatment over the other for nasal or eye symptoms at 6 and 8 weeks based on one poor quality trial132 (n=40) and one good quality trial131 (n=454). At 2 weeks, evidence also was insufficient to support the use of either treatment for these outcomes.

Comparisons involving intranasal corticosteroid that included trials of 2 and 4 weeks' duration
- Oral selective antihistamine versus intranasal corticosteroid: For nasal and eye symptoms, and quality of life as assessed by the Rhinitis Quality of Life Questionnaire (RQLQ), evidence was insufficient to support either treatment at both 2 weeks and 3 to 4 weeks.
- Combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine: For nasal and eye symptoms, evidence was insufficient to support the use of either treatment at both 2 and 4 weeks.

## Key Question 2 Comparative Harms of SAR Treatments in Adults and Adolescents 12 Years of Age or Older

We identified two comparisons with sufficient evidence to support the use of one treatment over the other in order to avoid harm while treating SAR symptoms. These are shown in Table 74. To avoid insomnia at approximately 2 weeks, moderate strength evidence supported the use of oral selective antihistamine rather than either monotherapy with an oral decongestant or combination therapy with oral selective antihistamine plus oral decongestant. For all other adverse events of interest, evidence to indicate superior harms avoidance with one treatment compared to another was either insufficient or lacking. Because MCIDs for harms outcomes have not been defined, equivalence of treatments compared was not tested and cannot be assumed.

Table 74 Summary of findings and strength of evidence of harms in 13 treatment comparisons: Key Question 2–adults and adolescents

Comparison | Headache | Sedation | Nosebleeds | Nasal Discomfort | Bitter Aftertaste | Burning | Anxiety | Insomnia | Palpitations | Dryness | Hypertension | Nasal Candidiasis | Nasal Atrophy | Odor Abnormality | Stinging
1. Oral S-AH vs. Oral nS-AH | Insuff^b^ | Insuff^b^
2. Oral S-AH vs. Nasal AH | Insuff^b^ | Insuff | Insuff^b^ | | Insuff^b^
3. Oral S-AH vs. INCS | Insuff^b^
4. Oral S-AH vs. Oral D | Insuff | Insuff | | | | | Insuff | Oral S-AH Moderate^a^
5. Oral S-AH vs. LRA | Insuff^b^
6. INCS vs. Nasal AH | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^
7. INCS vs. Nasal C | Insuff | | Insuff^b^ | Insuff | | Insuff^b^ | | | | Insuff
8. INCS vs. LRA | Insuff^b^ | | Insuff^b^
9. Oral S-AH + INCS vs. Oral S-AH | Insuff^b^ | Insuff^b^ | Insuff^b^ | | | Insuff^b^
10. Oral S-AH + INCS vs. INCS | Insuff^b^ | Insuff^b^ | Insuff^b^ | | | Insuff^b^
11. INCS + Nasal AH vs. INCS | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^
12. INCS + Nasal AH vs. Nasal AH | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^ | Insuff^b^
13. Oral S-AH + Oral D vs. Oral S-AH | Insuff | Insuff | | | | | Insuff | Oral S-AH Moderate^a^

C = cromolyn; D = decongestant; INCS = intranasal corticosteroid; LRA = leukotriene receptor antagonist; nS-AH = nonselective antihistamine; S-AH = selective antihistamine.

Entries indicate comparative efficacy conclusions supported by the evidence, or insufficient evidence to form a conclusion. Empty cells indicate outcomes that were not assessed.

Conclusions are indicated by Conclusion: Strength of evidence (SOE):

- “Oral S-AH” indicates sufficient evidence to support conclusions of superiority of oral selective antihistamine over its respective comparators to avoid the indicated harm.
- SOE is indicated by Low (low SOE), Moderate (moderate SOE), and High (high SOE).

“Insuff” indicates insufficient evidence to form a conclusion.

a Moderate strength evidence indicates fewer insomnia events at approximately 2 weeks with oral selective antihistamine.

b Based on trials that studied less than 50 percent of the drugs in at least one drug class compared.

As shown in Table 74, we made 46 harms assessments. Of these, 34 (74 percent) were based on drug class comparisons with less than 50 percent representation for at least one treatment compared. For these 34 assessments, conclusions may be limited to the specific drugs studied. As with effectiveness comparisons, the impact of poor representation may be limited for some drug classes (see “Overview of Results” for Key Question [KQ] 1, above).

We sought comparative information on a wide range of adverse events commonly associated with the pharmacologic classes studied. Conclusions about comparative harms are limited by the nature of the evidence reviewed in this report.

- Included trials lasted at most the duration of the pollen season, which is generally 6 to 8 weeks. Treatment durations were therefore relatively short for consideration of harms. Latent effects or cumulative effects from longer treatment durations are unknown.

Adverse events reported as the proportion of patients experiencing an event are assumed to be constant over time. This method of reporting does not differentiate between a person with a single episode of insomnia and one who experienced it every night of a 2-week trial. Adverse event frequencies often were not reported for all treatment groups. Harms assessment was inconsistent in the trials reviewed. Twenty-seven percent of trials indicated that an active method of harms surveillance was used. In contrast to passive surveillance, active surveillance of harms can yield qualitatively and quantitatively different results.144 However, we had to assume consistency of harms surveillance across trials to synthesize estimates and to consider a body of evidence for comparative review. To mitigate the effects of inconsistent harms surveillance on pooled effects (i.e., meta-analysis), we considered for pooling only events that either were considered severe by investigators or resulted in treatment discontinuation. We found no candidates for meta-analysis in any comparison. Adverse events collected for this review were categorized as mild, moderate, or severe as they were identified in the source publication, with the exception that all adverse events leading to treatment discontinuation were considered severe.

## Combined Evaluation of Key Questions 1 and 2 Comparative Effectiveness and Harms of Treatments in Adults and Adolescents 12 Years of Age or Older

We did not find evidence that any single treatment demonstrated both greater effectiveness and lower risk of harms. Table 75 shows the two comparisons for which there was sufficient evidence on reducing harms to form a conclusion along with the comparative effectiveness results for these comparisons. Moderate strength evidence supported the use of oral selective antihistamine to avoid insomnia associated with sympathomimetic decongestant at approximately 2 weeks (row 1 and row 2), but evidence was insufficient to support the use of one treatment over the other for effectiveness. (Equivalence was not assessed in either comparison due to the inability to conduct meta-analysis.) Similarly, of two treatments shown to be comparatively superior for effectiveness (row 3 and row 4), neither was preferred for harms avoidance.

Table 75 Comparison of efficacy and harms findings for two treatment comparisons

Comparison | Representation^a^ | Efficacy Outcome | Harms Outcome
1. Oral S-AH vs. Oral D | 80% vs. pseudoephedrine (50%) | Insufficient evidence^b^ | Oral S-AH to avoid insomnia: Moderate
2. Oral S-AH vs. Oral LRA | 60% vs. montelukast (100%) | Oral LRA for reduced asthma rescue medication use: Moderate | Insufficient evidence^b^
3. Oral S-AH + INCS vs. Oral S-AH | 40% Oral S-AH, 25% INCS | Oral S-AH + INCS for improved QoL: Low | Insufficient evidence^b^
4. Oral S-AH + Oral D vs. Oral S-AH | 80% Oral S-AH, pseudoephedrine (50%) | Insufficient evidence^b^ | Oral S-AH to avoid insomnia: Moderate

AH = antihistamine; D = sympathomimetic decongestant; LRA = leukotriene receptor antagonist; QoL = quality of life; S-AH = selective antihistamine.

Outcome entries indicate Conclusion: Strength of evidence. “Moderate” indicates moderate strength evidence to support the use of oral selective antihistamine over the indicated comparator to avoid insomnia.

a Representation indicates the proportion of drugs in each class that were studied.

b Insufficient evidence to support conclusions of superiority of one treatment over the other for efficacy or harms outcomes. Equivalence was not tested.

## Key Question 3 Comparative Effectiveness and Harms of SAR Treatments in Pregnant Women

For this KQ, we considered only Pregnancy Category B drugs, in which teratogenic effects have not been identified in animal studies or replicated in human studies. Evidence for the assessment of this KQ was lacking. No RCTs, observational studies, systematic reviews, or meta-analyses met the inclusion criteria.

Drugs used for the treatment of SAR have wide therapeutic windows (i.e., across the range of doses at which efficacy is seen, severe adverse events are not expected). Therefore, the choice of SAR treatment in pregnant women may be cautiously informed by comparative effectiveness evidence from the nonpregnant patient population. Because physiologic changes of pregnancy alter drug disposition, generalization of findings from the nonpregnant population to pregnant women requires knowledge of the magnitude and direction of these changes (Table 76). Due to a lack of study in pregnant women, current knowledge does not present a clear picture of safe and efficacious dosing adjustments of SAR treatments necessary to account for the physiologic changes of pregnancy.145 The minimum effective dose is generally preferred pregnancy.

Table 76 Physiologic changes in pregnancy and potential effects on drug disposition145,146

Physiologic parameter | Change compared with nonpregnant woman | Potential effect on drug disposition
Plasma volume | ↑ approximately 40-50% | ↑ Volume of distribution, ↓ peak serum concentrations
Plasma albumin concentration | ↓ approximately 15%^a^ | Alter protein binding (increase free fraction of protein bound [i.e., weakly acidic or weakly basic] drugs)
Serum pH | ↑slightly | May affect protein binding of weakly acidic/basic drugs
Cardiac output | ↑30-50%
Regional blood flow | uterus ↑ kidneys ↑ skin ↑ mammary glands ↑ hepatic↑ up to 160% skeletal muscle ↓ | May affect drug distribution and elimination (high extraction ratio drugs)
Glomerular filtration rate | ↑ 40-85% | Clearance of drugs eliminated renally
Hepatic metabolizing enzyme activity | N-demethylation ↓ CYP1A2 ↓ CYP2C19 ↓ CYP2C9 ↑ CYP2A6 ↑ CYP2D6 ↑/↓ CYP3A4 ↑ | Increase or decrease half-life
Gastric emptying | ↓ | Drug absorption increased
Gastric pH | ↑ | Altered depending on pH sensitivity

CYP = Cytochrome P450 isoenzyme.

a Plasma concentrations of total protein and α_1_-acid glycoprotein, which bind many basic drugs, are relatively unchanged during pregnancy.

## Key Question 4 Comparative Effectiveness and Harms of SAR Treatments in Children Younger Than 12 Years of Age

Of 21 treatment comparisons of interest among children, studies that met our inclusion criteria were identified for one, selective versus nonselective oral antihistamine. No observational studies, systematic reviews, or meta-analyses met the required inclusion criteria.

The evidence for effectiveness and for harms was insufficient to support the use of either oral selective antihistamine or nonselective antihistamine for the treatment of nasal or eye symptoms in children younger than 12 years of age (mean age 9 years, range 4 to 12 years). This finding was based on trials that studied 20 percent of oral selective antihistamines and 9 percent of oral nonselective antihistamines used to treat children. As with harms outcomes, a finding of insufficient evidence to support a conclusion of superiority of one treatment over the other does not imply equivalence of the treatments. The evidence for benefit was truly insufficient; equivalence was not assessed.

## Findings in Relationship to What Is Already Known

The following three systematic reviews provide current information about the pharmacologic treatment of allergic rhinitis. Each provided a description of the literature search, inclusion and exclusion criteria for identified trials, and quality assessments of included trials. Thus, the risk of bias was considered low for each. Two of the reviews were published before 2010, the cutoff date for potential incorporation of results into this review. Results from the third review were not incorporated into this review due to methodological differences; for example, the 2010 review was based on previously published systematic reviews, and disease was not limited to SAR. For purposes of comparing our findings to current knowledge, we included high-quality seminal works by relevant groups regardless of publication date.

- Guidelines for the treatment of allergic rhinitis from the international Allergic Rhinitis and Its Impact on Asthma (ARIA) working group, updated in 2010^28^

A 2009 systematic review of treatments for hay fever147

A 2008 Practice Parameter on the diagnosis and management of rhinitis from the Joint Task Force on Practice Parameters, representing the American Academy of Allergy, Asthma & Immunology (AAAAI), the American College of Allergy, Asthma and Immunology (ACAAI), and the Joint Council of Allergy, Asthma and Immunology (JCAAI)3

A 2010 systematic review of SAR treatments by drug class41 is not included in this list because quality assessments of included trials were not reported.

Findings from each of these reports are compared with those of this comparative effectiveness review in Table 77. Of 13 comparisons for which we found studies, three were not addressed by the systematic reviews. In two of the remaining ten comparisons, our conclusions agreed with at least one of the systematic reviews (ARIA guidelines in both instances). For five of eight discordant conclusions, other systematic reviews formed comparative effectiveness or harms conclusions, and we found insufficient evidence to do so. The other three discordant conclusions involved intranasal corticosteroid alone or in combination. We concluded comparable effectiveness (equivalence) of the treatments compared, and other systematic reviews concluded comparative superiority of intranasal corticosteroid. The eight discordant conclusions are reviewed below. In all cases, differing conclusions could be attributed to differences in inclusion criteria for trials reviewed.

Table 77 Comparison of findings from four systematic reviews of treatments for seasonal allergic rhinitis

Comparison | ARIA28 | Sheikh147 | AAAAI3,a | AHRQ CER | Agreement
1. Oral S-AH vs. Oral nS-AH | Oral S-AH to avoid harms Low quality evidence in AR | | Oral S-AH to avoid sedation, performance impairment, and anticholinergic effects B | Insufficient evidence for superiority or harms avoidance | Discordant results
2. Oral S-AH vs. Nasal AH | Oral S-AH to avoid bitter aftertaste Moderate quality evidence in SAR | Mixed oral S-AH and nS-AH comparable to nasal AH for nasal symptoms and harms Moderate-quality evidence | Nasal AH is equal to or superior to oral S-AH for SAR A | Insufficient evidence for superiority or harms avoidance | Discordant results
3. Oral S-AH vs. INCS | INCS preferred over mixed oral S-AH and nS-AH based on efficacy Low quality evidence in SAR | INCS preferred to mixed oral S-AH and nS-AH for nasal symptoms. Comparable efficacy for eye symptoms Low-quality evidence | | Insufficient evidence for superiority, equivalence or harms avoidance | Discordant results
4. Oral S-AH vs. Oral D | | | | Oral S-AH to avoid insomnia - Moderate SOE | No comparison
5. Oral S-AH vs. LRA | Comparable for efficacy and harms. Oral AH recommended based on cost Moderate quality evidence in SAR | Low-quality evidence does not permit an efficacy conclusion Comparable for harms | | Equivalence for nasal and eye symptoms and QoL; LRA for asthma symptom - Moderate SOE | Agree with ARIA
6. INCS vs. Nasal AH | INCS preferred based on efficacy High quality evidence in mixed SAR/PAR | INCS preferred for nasal symptoms Nasal AH preferred for eye symptoms Very low-quality evidence Bitter taste more common with nasal AH (azelastine) than with INCS (fluticasone) | INCS preferred for treatment of AR A | Equivalence for nasal and eye symptoms - High SOE | Discordant results
7. INCS vs. Nasal C | | | INCS preferred in most patients with AR; nasal C effective in some patients for prevention and treatment of AR with minimal harms A | Insufficient evidence for superiority or harms avoidance | Discordant results
8. INCS vs. LRA | INCS preferred over LRA based on efficacy Low quality evidence in SAR | INCSA preferred for nasal symptoms High quality evidence Comparable harms | | Equivalence for nasal symptoms - High SOE | Discordant results
9. Oral S-AH + INCS vs. Oral S-AH | | | | Oral S-AH + INCS for QoL - Low SOE | No comparison
10. Oral S-AH + INCS vs. INCS | | Oral S-AH + INCS for QoL at 2 weeks Low-quality evidence | | Insufficient evidence for superiority or harms avoidance | Discordant results
11. INCS + Nasal AH vs. INCS | | | | Equivalence for nasal and eye symptoms - High SOE | No comparison
12. INCS + Nasal AH vs. Nasal AH | | INCS + Nasal AH (azelastine) for nasal symptoms at 2 weeks Moderate-quality evidence | | Equivalence for nasal and eye symptoms - High SOE | Discordant results
13. Oral S-AH + Oral SD vs. Oral S-AH | Oral AH (mixed S-AH and nS-AH) monotherapy despite greater benefit (small) with combo because harms reported more often with combo Moderate evidence in mixed SAR/PAR | Oral S-AH + oral SD (pseudoephedrine) for nasal symptoms at 2−10 weeks Moderate-quality evidence | | Oral S-AH to avoid insomnia - Moderate SOE | Agree with ARIA

AAAAI = American Academy of Allergy, Asthma & Immunology; AH = Antihistamine; AHRQ = Agency for Healthcare Research and Quality; ARIA = Allergic Rhinitis and Its Impact on Asthma; C = cromolyn; CER = comparative effectiveness review; D = decongestant; INCS = intranasal corticosteroid; LRA = leukotriene receptor antagonist; nS-AH = nonselective antihistamine; QoL = quality of life; S-AH = selective antihistamine; SOE = strength of evidence.

a Strength of recommendation ratings are based on the level of evidence. An A recommendation is directly based on category I evidence, defined as evidence from meta-analysis of randomized controlled trials or evidence from at least 1 randomized controlled trial. A B recommendation is directly based on category II evidence or extrapolated from category I evidence. Category II evidence is defined as evidence from at least 1 controlled study without randomization or evidence from at least 1 other type of quasi-experimental study.3

Discordant conclusions of insufficient evidence
- Oral selective antihistamine versus oral non-selective antihistamine: ARIA guidelines28 and the AAAAI practice parameter3 recommended oral selective antihistamine to avoid harms. ARIA did not provide an evidence profile for this comparison. Evidence to inform AAAAI's recommendation included observational data and comparative studies in healthy volunteers.
- Oral selective antihistamine versus nasal antihistamine: ARIA guidelines28 recommended oral selective antihistamine for avoidance of harms, such as bitter aftertaste. This review included trials of non-Food and Drug Administration (FDA) approved oral antihistamines (ebastine and levocabastine) and a trial in perennial allergic rhinitis (PAR). The other two reviews3, ^149^ reported comparable efficacy of the treatments. One147 of these conclusions was based on a trial of a non-FDA approved nasal antihistamine (levocabastine) in comparison with a non-FDA approved oral antihistamine (terfenadine). The other3 included a pharmacodynamic study in an environmental exposure chamber and a trial of combination therapy not identified as an intervention of interest for the present review.
- Oral selective antihistamine versus intranasal corticosteroid: Two reviews28, 147 found evidence favoring intranasal corticosteroid over mixed oral selective and non-selective antihistamine. One^149^ of these included two trials that reported only physiologic outcomes (e.g., nasal airflow), and the other28 included trials in PAR.
- Intranasal corticosteroid versus nasal cromolyn: The AAAAI practice parameter3 recommended intranasal corticosteroid for most patients based on a single trial125 that was one of four trials included in the present review for this comparison.
- Combination oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid: One review147 reported greater improvement in quality of life with combination therapy than with intranasal corticosteroid monotherapy based on one trial. This trial62 was one of five trials included in the present review for this comparison.

Discordant conclusions of comparable effectiveness (equivalence)
- Intranasal corticosteroid versus nasal antihistamine: All three reviews supported the use of intranasal corticosteroid based on a systematic review29 that included patients with PAR.
- Intranasal corticosteroid versus oral leukotriene receptor antagonist: Two reviews28, 147 found evidence to support the use of intranasal corticosteroid for symptoms of AR28 and SAR.147 In both of these, conclusions were based on statistical rather than clinical significance of treatment effects reported by two128, 129 (in the ARIA guidelines28) or four126-129 (in the 2009 systematic review^149^) of five trials97, 126-129 included in the present review for this comparison.
- Combination intranasal corticosteroid plus nasal antihistamine versus nasal antihistamine: One review147 found evidence to support the use of combination therapy over nasal antihistamine (azelastine) monotherapy based on one121 of five115, 117, 121 trials included in the present review for this comparison. Four trials115, 117 were published after the systematic review.147

## Applicability

Applicability is assessed in terms of PICOTS—populations, interventions, comparisons, outcomes, timeframes, and settings of care.79

[underlined: Populations]: In studies that reported the ethnic-racial make-up of trial participants, most patients were white. Approximately 9 percent were black, 7 percent were Hispanic, and 3 percent were Asian. Adult patients tended to be in their 30s and 40s. Some trials included older patients. This population is representative of many patients with SAR. Results are likely to be generalizable to adults of different ethnicities or ages, although this is not known with certainty. Patients in their seventh or eighth decade of life may require dosage adjustments for reduced renal or liver function and greater vigilance for adverse events, for example, sedating effects.

Most patients had moderate to severe symptoms at baseline and had a minimum 5-year duration of SAR. Evidence from three small trials that studied patients with mild symptoms,122, 128, 130 was insufficient to suggest that mild nasal symptoms respond differently than moderate/severe symptoms to the specific treatments compared. Only one130 of these trials reported disease duration; 92 percent of patients had SAR for more than 5 years. Applicability of the findings from this report to patients with mild or recent onset SAR is therefore unknown.

[underlined: Interventions/Comparisons]: The interventions investigated represent treatment options for SAR currently available in the United States. We restricted our search to trials that used FDA-approved drugs at FDA-approved doses. Conclusions may not be applicable to drugs in included drug classes that were not specifically studied (e.g., drugs or doses used in Europe). Additionally, for comparisons with trials studying a small proportion of the drugs in a class, applicability of the findings to other drugs in the class that were not studied is uncertain. We did not assess eye drops for the treatment of eye symptoms associated with SAR. We sought but did not find sufficient comparative trials to address as-needed dosing.

[underlined: Outcomes]: SAR symptoms comprise nasal, eye, ear, palate, and throat symptoms. To maximize comparability across trials, we focused on the most often reported nasal and eye symptom outcomes, which likely enhances generalizability. For patients who experience less common symptoms, such as postnasal drip or ear itching, results from this report may not be generalizable. Outcomes were reported within the time frames of their trials and comparators; for example, nasal outcomes at 2 and 4 weeks were not mixed for trials involving intranasal corticosteroid, but were mixed for trials involving other drugs of more uniform onset and duration of action. It is unclear whether results from shorter intervals are generalizable to longer use, for example, whether treatment effectiveness reported at earlier time points is maintained at later time points and whether the incidence of adverse effects increases with increased duration of exposure.

[underlined: Timeframes]: By limiting diagnosis specifically to SAR, we excluded not only patients with PAR but also those classified according to the new criteria proposed by the ARIA group,28 that is, those diagnosed with intermittent allergic rhinitis or persistent allergic rhinitis. These categories define overlapping but differing patient populations.3 Diagnostic categories vary in at least two dimensions: duration of allergen exposure and type of allergen. Because treatments are symptomatic, it is not expected that type of allergen will affect treatment response. However, duration of allergen exposure and, consequently, of treatment exposure may impact the applicability of the findings. For the assessment of treatment effectiveness in real-world settings, we included studies with a 2-week minimum treatment duration during pollen season.50 Study duration was therefore limited by the natural pollen cycle. We searched for trials of longer duration to compare short-term (weeks) and longer-term (months) effectiveness and harms, but the few trials of longer than 4 weeks' duration identified prevented definitive conclusions. Similarly, patients who require less than 2 weeks' treatment may experience different effects than those reported here.

[underlined: Settings]: Of all trials identified, only one was not set in Europe or North America. This was a trial of 50 patients conducted in Asia (Nepal).116 Across all trials, Asian patients represented a minor fraction of patients studied. Generalizability to patients in Asia or to Asian patients in North America or Europe may be limited by differing aeroallergen exposure and by potential genotype differences affecting metabolism of drugs used to treat SAR.

## Implications for Clinical and Policy Decisionmaking

Fortunately, SAR is not a life-threatening disease. Consideration of risks and benefits of treatment therefore shifts, from an expectation that adverse events may accompany effective treatments to an appreciation that adverse effects of treatment may be worse than the disease itself. We did not find high strength evidence for differences in effectiveness or adverse effects in any treatment comparison. We did find high strength and moderate strength evidence for comparable effectiveness of several treatments for several outcomes, low strength evidence for superiority of two treatments for two outcomes, and moderate strength evidence for the avoidance of insomnia.

This evidence may be insufficient for policy decisionmaking. For example, although conclusions of comparable effectiveness may suggest that differential costs of treatments are unwarranted, lack of evidence to evaluate comparative harms of these treatments prohibits full assessment of their risk-benefit profiles.

For clinical decisionmaking, conclusions of comparable effectiveness suggest that patient preferences and priorities can contribute significantly to treatment choice. When considering the balance between effectiveness and harms in relatively healthy individuals, potential harms may acquire greater weight.144

## Limitations of the Comparative Effectiveness Review Process

To narrow the scope of this project to a manageable size, we made several decisions at the start that had downstream consequences. These included:

- We restricted diagnosis to SAR. Given the current state of transition between classification schemes for allergic rhinitis, use of the original scheme may have excluded some trials. However, it is acknowledged that SAR and intermittent allergic rhinitis define different patient populations.3 We decided to pick one disease to study and then find studies similar enough to compare results. Introducing studies of allergic rhinitis classified according to the newer scheme may have added to the variability of included studies.
- We did not examine every possible treatment comparison. Rather, guided by input from Key Informants and the TEP, we prioritized comparisons that reflect treatment decisions encountered in the clinical setting. It is hoped that we selected, and found evidence to assess, comparisons that are meaningful to users of this report.
- We excluded trials of one drug versus a placebo and focused on direct comparisons only. This decision was based on feasibility concerns given the large scope of the project and time constraints. Harms assessment was limited by the absence of placebo groups, which can inform adverse event reporting particularly.
- We included FDA-approved drugs only. For the comparison of oral selective antihistamine to oral nonselective antihistamine in particular, this significantly reduced the number of included trials. The majority of these trials used terfenadine or astemizole as the selective antihistamine comparator, neither of which is currently FDA-approved due to postmarketing safety concerns. As a result, only three trials were included for this comparison.
- Our minimum 2-week duration excluded examination of other treatment features that may be important to patients, e.g., onset of action and harms associated with shorter exposure. However, harms associated with the interventions as defined (i.e., minimum 2-week exposure) were included. Trials less than 2 weeks' duration often did not replicate natural methods of exposure to airborne allergens (i.e., used instead environmental exposure chambers, direct application of allergen, or prolonged weekend visits to parks), and results may be less applicable.
- As described below, reporting of efficacy outcomes in SAR research currently is nonstandard. To maximize our ability to compare outcomes across trials, we selected the most commonly used symptom measures, namely the four-symptom TNSS and the three-item total ocular symptom score (TOSS). Data from trials that used variations on these reporting scales could not be incorporated into the report. Symptoms potentially important to patients but seldom assessed (e.g., post-nasal drip, and ear and palate itching) were not included in this review.
- The scope of this report is class comparisons of SAR treatments. As a consequence of this approach, individual drug comparisons were beyond the scope of this report. Also, for comparisons with trials studying a small proportion of the drugs in a class, we were limited in our ability to make conclusions about entire pharmacologic classes, particularly for larger classes such as intranasal corticosteroids and oral nonselective antihistamines. As discussed above (in the Discussion of KQ1), the impact of this limitation may be small for certain drug classes, such as oral nonselective antihistamine, which are less commonly used, and oral decongestant, of which the more commonly used drug was studied.
- Limitations in the quality of trial reporting impacted directly the conclusions that could be drawn and strength of evidence ratings. For example, insufficient group-level data reporting prevented equivalence assessments. Insufficient descriptions of analyses compromised quality ratings. For example, if intention-to-treat (ITT) analysis was not specified, or insufficient patient flow data were provided to determine that an ITT analysis was done, trial quality was rated poor. This was a conservative decision that was warranted. It is hoped that continued implementation of guidelines for trial reporting will address such difficulties.

## Limitations of Evidence Base

In their review of SAR treatments, Benninger et al. (2010) conclude that “the reporting of published data should be standardized to permit comparisons among treatments.”41 The following six improvements are cited:

- Standard inclusion criteria for allergic rhinitis based on a unified definition
- Standard stratification of disease severity
- TNSS based on four nasal symptoms (congestion, rhinorrhea, sneezing, and nasal itch) and reported on a 3-point or 4-point severity scale
- Standard ocular data for TOSS
- Standard quality of life data using a validated survey
- Standard age cutoffs (adult studies should include ages > 18 years; adolescents, 12–18 years old; school-age children, 6–11 years old)

In our experience, factors 2, 3, 4, and 6 reduced our ability to draw evidence-based conclusions. Additionally, evidence for efficacy and harms in patients with mild disease was lacking due to enrollment of patients primarily with moderate/severe disease. In fact, standard definitions of mild, moderate, and severe disease in terms of symptom scales do not currently exist. A 4-point scale may be divided into terciles (0-1 mild, 1-2 moderate, 2-3 severe), but this is an empirical division. It is unknown whether the scale is linear in patients' experience.

We could not incorporate several trials that reported only total symptom scores, comprising nasal, eye, ear, and palate symptoms. Standard reporting of the four-symptom TNSS and the three-symptom TOSS would greatly facilitate treatment comparisons. It is surprising that the list above does not include a call for well-defined MCIDs for symptom scales. Although our selection of clinically informed MCIDs permitted us to draw clinically relevant conclusions, validation of the values used (30 percent maximum score) using anchor-based approaches is desirable. Without such well-defined MCIDs, at least three analytic tools important for clinical research–power calculations, non-inferiority margins, and responder analyses–are compromised.

Another methodological issue is the incomplete reporting of results. Examples include:

- Reporting the results of statistical testing for only two arms of a three-arm trial
- Not reporting variance estimates for group-level treatment effects
- Not reporting results for all identified outcomes
- Missing baseline symptom or quality of life scores
- Partial accounting of patient flow through the trial

Adverse event reporting was consistently incomplete. Severity of adverse events was sometimes mentioned, but, as above, lack of standard definitions of severity or a standard adverse event scale currently limits the usefulness of severity descriptions. Adverse events often were not reported by treatment group or were not identified. That is, the proportion of patients experiencing adverse events was at times reported without any description of the adverse events experienced.

We excluded several trials that did not report results by age groups or that formed age groups using non-standard cut points. Defining “adolescent” from age 12 may be arbitrary, but its general adoption would permit greater learning about this age group. FDA commonly uses a cut point of age 12 for dosing of SAR drugs in children and adolescents.

Finally, within the constraints of our inclusion criteria, we identified few to no studies for the assessment of SAR treatments in pregnant women and children. Head-to-head active comparator trials may be ethically difficult in these vulnerable populations unless true equipoise exists. Although we preferred RCTs, we would have included relevant nonrandomized comparative trials, but we found none.

## Research Gaps

The greatest need in SAR research is increased methodological rigor. Widely used symptom rating scales require standardization and validation. Lack of anchor-based MCIDs is a major deficiency. Agreed-upon reporting standards for effectiveness and harms outcomes are needed. Agreed-upon classifications of patients by age and standardized definitions of symptom and harms severity also are needed. Study designs that can more efficiently assess the effects of additive therapies are lacking. That is, studies in which all patients are treated with one component of a combination (e.g., oral selective antihistamine) and only those who are resistant receive the second component (e.g., intranasal corticosteroid) may more efficiently isolate the additive effect of the second component. We identified one trial with this design.148

Lack of evidence on populations of interest is a research gap. Currently, the majority of trial participants are relatively homogenous: white and middle-aged with moderate/severe SAR symptoms. Inclusion of different races, greater proportions of patients toward both ends of the age spectrum, and patients with mild symptoms may inform our understanding not only of the comparative effectiveness and harms of SAR treatments in different groups, but also of the expression of SAR in various ethnic groups, the natural history of the disease across the life span, and the effect (if any) of early treatment on later symptom expression. As noted above, however, ethical considerations may limit the inclusion of vulnerable populations (e.g., children) in well-designed studies of pharmacologic interventions.

For pregnant women, pregnancy registries and rigorous studies based on the data therein can fill the gap. Additionally, greater understanding of how the physiologic changes of pregnancy affect the magnitude and direction of change in drug disposition may facilitate application of effectiveness and safety findings from the nonpregnant population to pregnant women. This presumes use of Pregnancy Category B drugs to avoid potential known or unknown teratogenic effects of other drugs.

## Conclusions

For most treatment comparisons of interest, evidence was insufficient to support conclusions about comparative effectiveness and harms. Of conclusions that could be drawn, most suggested comparable effectiveness of treatments compared. For adults and adolescents over the age of 12 we found:

- High strength evidence for comparable effectiveness (equivalence) of:
  ○ Combination intranasal corticosteroid (fluticasone propionate) plus nasal antihistamine (azelastine), intranasal corticosteroid monotherapy, and nasal antihistamine monotherapy for nasal and eye symptoms at 2 weeks.
  ○ Intranasal corticosteroid and oral leukotriene receptor antagonist (montelukast) for nasal symptoms at 2 weeks.
- Moderate strength evidence for comparable effectiveness of oral selective antihistamine and oral leukotriene receptor antagonist for nasal and eye symptoms and for improved quality of life at 2-4 weeks.

In this population, we found evidence for the superiority of:

- Oral selective antihistamine over both oral decongestant and combination oral selective antihistamine plus oral decongestant to avoid insomnia at approximately 2 weeks (moderate strength evidence).
- Oral leukotriene receptor antagonist over oral selective antihistamine for reduced asthma rescue medication use at 2-4 weeks (moderate strength evidence).
- Combination oral selective antihistamine plus intranasal corticosteroid over oral selective antihistamine monotherapy for improved quality of life at 2-4 weeks (low strength evidence).

Conclusions about symptom improvement were based on clinically informed but non-validated MCIDs. Sensitivity analyses supported the conclusions above as well as the use of combination oral selective antihistamine plus oral decongestant over oral selective antihistamine monotherapy for nasal symptoms. The lack of comparative evidence for all drugs within each class limited the applicability of conclusions. Evidence was insufficient or lacking to support any of 48 other identified treatment comparisons of interest among adults and adolescents over the age of 12, pregnant women, and children younger than 12 years of age.