# McMaster Quality Assessment Scale of Harms (McHarm)

## Rating

- Were the harms PRE-DEFINED using standardized or precise definitions?
  - Yes
  - No
  - Unsure
- Were SERIOUS events precisely defined?
  - Yes
  - No
  - Unsure
- Were SEVERE events precisely defined?
  - Yes
  - No
  - Unsure
- Were the number of DEATHS in each study group specified OR were the reason(s) for not specifying them given?
  - Yes
  - No
  - Unsure
- Was the mode of harms collection specified as ACTIVE?
  - Yes
  - No
  - Unsure
- Was the mode of harms collection specified as PASSIVE?
  - Yes
  - No
  - Unsure
- Did the study specify WHO collected the harms?
  - Yes
  - No
  - Unsure
- Did the study specify the TRAINING or BACKGROUND of who ascertained the harms?
  - Yes
  - No
  - Unsure
- Did the study specify the TIMING and FREQUENCY of collection of the harms?
  - Yes
  - No
  - Unsure
- Did the author(s) use STriamcinolone acetonide NDARD scale(s) or checklist(s) for harms collection?
  - Yes
  - No
  - Unsure
- Did the authors specify if the harms reported encompass ALL the events collected or a selected SAMPLE?
  - Yes
  - No
  - Unsure
- Was the NUMBER of participants that withdrew or were lost to follow-up specified for each study group?
  - Yes
  - No
  - Unsure
- Was the TOTriamcinolone acetonide L NUMBER of participants affected by harms specified for each study arm?
  - Yes
  - No
  - Unsure
- Did the author(s) specify the NUMBER for each TYPE of harmful event for each study group?
  - Yes
  - No
  - Unsure
- Did the author(s) specify the type of analyses undertaken for harms data?
  - Yes
  - No
  - Unsure