# Data Abstraction Form Elements

## Population Form

- Is the reference about adults, children or pregnant women?
  ○ Adults
  ○ Children
  ○ Pregnant women

## Study Characteristics Form

- First Author (last name, first name)
- Publication Year
- Study Location
  ○ North America
  ○ Europe
  ○ Asia
  ○ Other (specify)
  ○ Multicontinental
- Does the reference have a single or multiple sites?
  ○ Single
  ○ Multiple
- Enrollment month, year- XX/XXXX
- Funding
  ○ Industry
  ○ Academia
  ○ Academia
  ○ Not reported
  ○ Other
- Were author industry relationships disclosed/identified?
  ○ Yes
  ○ No
  ○ Not Reported
- Study Design
  ○ RCT
  ○ Quasi-RCT
  ○ Controlled (non-randomized) clinical trial
  ○ Population-based cohort study
  ○ Case-control study
  ○ SR/MA
- Intervention N:
  ○ Total number of patients randomized:
  ○ Total number of patients analyzed:
- SAR diagnosis objectively confirmed?
  ○ Yes
  ○ No
- Inclusion criteria:
  ○ Minimum SAR severity:
  ○ Minimum SAR duration:
  ○ Both:
- Exclusion criteria:
  ○ SAR medication restrictions
  ○ Other medication restrictions
  ○ Chronic asthma
  ○ Immunotherapy
  ○ Pregnancy
  ○ Respiratory infection
  ○ Anatomical deformities
  ○ Sleep apnea
  ○ Other:
- Other symptom-relieving medications allowed?
  ○ Yes
  ○ No
- Duration of treatment (weeks)
- Duration of follow-up (weeks)
  ○ Number of weeks
  ○ Not reported
- Were pollen counts measured
  ○ Yes
  ○ No
- Blinding
  ○ Patient
  ○ Assessor
  ○ Inadequate patient blinding
  ○ Inadequate assessor blinding
  ○ Open-label trial (not blinded)
  ○ Not reported
- Was a VAS scale used?
- Interval NSS definitions
  ○ Mild
  ○ Moderate
  ○ Severe
- Total nasal symptom scale used
  ○ Sum
  ○ Mean
- TNSS daily maximum score

## Group Characteristics Form

- Group
  ○ Group One
  ○ Group Two
  ○ Group Three
  ○ Group Four
- Component 1
  ○ Drug class
    - Intranasal corticosteroid
    - Selective antihistamine, oral
    - Selective antihistamine, nasal
    - Non-selective antihistamine, oral
    - Intranasal anticholinergic
    - Intranasal mast cell stabilizer
    - Oral decongestant
    - Intranasal decongestant
    - Oral LRA
    - Nasal saline
  ○ Drug dose
  ○ Frequency
  ○ Total daily dose
- Component 2
  ○ Drug class
    - Intranasal corticosteroid
    - Selective antihistamine, oral
    - Selective antihistamine, nasal
    - Non-selective antihistamine, ora
    - Intranasal anticholinergic
    - Intranasal mast cell stabilizer
    - Oral decongestant
    - Intranasal decongestant
    - Oral LRA
    - Nasal saline
  ○ Drug dose
  ○ Frequency
  ○ Total daily dose

## Patient Characteristics Form

- Group
  ○ Group One
  ○ Group Two
  ○ Group Three
  ○ Group Four
- Patient population
- Age
  ○ Mean
  ○ Median
  ○ Range
  ○ SD
  ○ IQR
- % Female- XX.X
- % Race- XX.X
  ○ Mean
  ○ Median
  ○ Range
  ○ SD
  ○ IQR
  ○ Other
- Disease duration (years)
  ○ Mean
  ○ Median
  ○ Range
  ○ SD
  ○ IQR
  ○ Other

## Symptom Outcomes Form

- Group
  ○ Group One
  ○ Group Two
  ○ Group Three
  ○ Group Four
- Total number of patients randomized:
- Total number of patients analyzed:
- Outcome measurement type
  ○ Reflective
  ○ Instantaneous
  ○ AM
  ○ PM
  ○ Reflective -AM
  ○ Reflective -PM
  ○ Instantaneous -AM
  ○ Instantaneous -PM
  ○ Other
    a. Not specified
- Time Point
  ○ 2 weeks
  ○ 3 weeks
  ○ 4 weeks
  ○ 2 months
  ○ 3 months
  ○ 4 months
  ○ 6 months
  ○ Other
  ○ Not specified
- Label
  ○ Endpoint
  ○ Overall/Mean
  ○ Relative
  ○ Interval/Mean
  ○ Uncertain
- Outcome
  ○ NSS, congestion
  ○ NSS, rhinorrhea
  ○ NSS, sneezing
  ○ NSS, nasal itching
  ○ TNSS
  ○ Asthma
  ○ TOSS
  ○ School performance
  ○ Other medication/rescue med use
- Outcome measure
  ○ Pre Mean (SD)
  ○ Pre Median (range)
  ○ Post Mean (SD)
  ○ Post Median (range)
  ○ Change Mean (SD)
  ○ Change 95% CI
- Cough mentioned?
  ○ Yes
  ○ No
- Adherence assessed?
  ○ Yes (% adherence)
  ○ No
- Are other outcomes available?

## Function and Quality of Life Outcomes Form

- Group
  ○ Group One
  ○ Group Two
  ○ Group Three
  ○ Group Four
- QoL outcomes mentioned?
  ○ Yes
  ○ No
- Total number of patients randomized:
- Total number of patients analyzed:
- Time Point
  ○ 2 weeks
  ○ 3 weeks
  ○ 4 weeks
  ○ 2 months
  ○ 3 months
  ○ 4 months
  ○ 6 months
  ○ Other
  ○ Not specified
- Quality of Life outcomes
  ○ RQLQ
  ○ Mini-RQLQ
  ○ Rhinasthma QLQ
  ○ Nocturnal RQLQ
  ○ SF-36
  ○ PGA
  ○ Epworth
- Outcome measure
  ○ Pre Mean (SD)
  ○ Pre Median (range)
  ○ Post Mean (SD)
  ○ Post Median (range)
  ○ Change Mean (SD)
  ○ Change 95% CI

## Comparisons Form

- Is a statistical test performed?
  ○ Yes
  ○ No
- Statistical Test
  ○ Kruskal-Wallis
  ○ Mann Whitney U
  ○ ANOVA
  ○ Wilcoxon rank sum test
  ○ Chi-square
  ○ T-test
  ○ ANCOVA
  ○ Other
- Outcome measurement type
  ○ Reflective
  ○ Instantaneous
  ○ AM
  ○ PM
  ○ Reflective -AM
  ○ Reflective -PM
  ○ Instantaneous -AM
  ○ Instantaneous -PM
  ○ Other
  ○ Not specified
- Time point
  ○ Pre
  ○ 2 weeks
  ○ 3 weeks
  ○ 4 weeks
  ○ 2 months
  ○ 3 months
  ○ 4 months
  ○ 6 months
  ○ Other
  ○ Not specified
- Label
  ○ Endpoint
  ○ Overall/Mean
  ○ Relative
  ○ Interval/Mean
  ○ Uncertain
- Comparison between groups
  ○ 1 vs. 2
    - p-value
  ○ 1 vs. 3
    i. p-value
  ○ 2 vs. 3
    ii p-value
  ○ Multiple group comparisons
    - p-value
- Outcome
  ○ NSS, congestion Mean difference (95% CI)
  ○ NSS, sneezing Mean difference (95% CI)
  ○ NSS, rhinorrhea Mean difference (95% CI)
  ○ NSS, nasal itching Mean difference (95% CI)
  ○ TNSS
  ○ Rescue med use Ratio (95% CI)
  ○ TOSS Mean difference (95% CI)

## Function and QoL Comparisons Form

- Is a statistical test performed?
  ○ Yes
  ○ No
- Statistical Test
  ○ Kruskal-Wallis
  ○ Mann Whitney U
  ○ ANOVA
  ○ Wilcoxon rank sum test
  ○ Chi-square
  ○ T-test
  ○ ANCOVA
  ○ Other
- Time point
  ○ Pre
  ○ 2 weeks
  ○ 3 weeks
  ○ 4 weeks
  ○ 2 months
  ○ 3 months
  ○ 4 months
  ○ 6 months
  ○ Other
  ○ Not specified
- Comparison between groups
  ○ 1 vs. 2
    - p-value
  ○ 1 vs. 3
    - p-value
  ○ 2 vs. 3
    - p-value
  ○ Multiple group comparisons
    - p-value
- Quality of Life outcomes
  ○ Test result (95% CI)
  ○ Mini-RQLQ Test result (95% CI)
  ○ RQLQ Rhinasthma QLQ Test result (95% CI)
  ○ Nocturnal RQLQ Test result (95% CI)
  ○ SF-36 Test result (95% CI)
  ○ PGA Test result (95% CI)
  ○ Epworth Test result (95% CI)

## Adverse Events Form

- Group
  ○ Group One
  ○ Group Two
  ○ Group Three
  ○ Group Four
- AEs mentioned?
  ○ Yes
  ○ No
- N (number analyzed)
- Type of adverse event by severity
  ○ Mild AEs reported -- % XX.X
  ○ Moderate AEs reported -- % XX.X
  ○ Severe AEs reported -- % XX.X
  ○ Unspecified severity AEs reported -- % XX.X
    - Sedation
    - Headache
    - Stinging
    - Dryness
    - Burning
    - Impaired work/school performance
    - Odor abnormalities
    - Bitter aftertaste
    - Hypertension
    - Palpitations
    - Insomnia
    - Anxiety
    - Nosebleeds
    - Rhinitis medicamentosa
    - Increased intraocular pressure
    - Cataract formation
    - Nasal septal atrophy
    - Fungal infection
    - Adrenal suppression
    - Hyperglycemia
    - Bone demineralization/fracture
    - Growth delay in children
    - Traffic accidents
    - Nasal discomfort

## Study Quality

### RCT Quality Assessment (USPSTF)

- Power calculation reported?
  ○ Yes
  ○ No
- Assembly of comparable groups
  ○ Yes
  ○ No
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
  ○ Yes
  ○ No
  ○ Uncertain
- Minimal loss to followup (<20% each treatment arm)
  ○ Yes
  ○ No
- Interventions comparable/ clearly defined
  ○ Yes
  ○ No
  ○ Uncertain
- All important outcomes considered
  ○ Yes
  ○ No
- Appropriate analysis of results (adjustment for potential confounders and intention-to-treat analysis)
  ○ Yes
  ○ No
- Overall Rating
  ○ Good
  ○ Fair
  ○ Poor

### AE Reporting Quality Assessment, McMaster

- Were the harms pre-defined using standardized or precise definitions?
  ○ Yes
  ○ No
  ○ Uncertain
- Were serious events precisely defined?
  ○ Yes
  ○ No
  ○ Uncertain
- Were severe events precisely defined?
  ○ Yes
  ○ No
  ○ Uncertain
- Was the mode of harms collection specified as active?
  ○ Yes
  ○ No
  ○ Uncertain
- Was the mode of harms collection specified as passive?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the study specify who collected the harms?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the study specify the training or background of who ascertained the harms?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the study specify the timing and frequency of collection of the harms?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the author(s) use standard scale(s) or checklist(s) for harms collection?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the authors specify if the harms reported encompass all the events collected or a selected sample?
  ○ Yes
  ○ No
  ○ Uncertain
- Was the number of participants that withdrew or were lost to follow-up specified for each study group?
  ○ Yes
  ○ No
  ○ Uncertain
- Was the total number of participants affected by harms specified for each study arm?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the author(s) specify the number for each type of harmful event for each study group?
  ○ Yes
  ○ No
  ○ Uncertain
- Did the author(s) specify the type of analyses undertaken for harms data?
  ○ Yes
  ○ No
  ○ Uncertain