# Evidence Tables

## Oral Selective Antihistamine Versus Oral Nonselective Antihistamine

Appendix Table C1 Trial description: oral selective antihistamine versus oral nonselective antihistamine

Author, Year | Location/Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in \Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Dockhorn, 1987 | N. America Multiple | April 1985 2 weeks | NR NR | 220 | Minimum SAR severity | SAR meds/- Other meds Chronic asthma Pregnancy | No | • | | | • | •
Harvey, 1996 | N. America Multiple | 2 weeks | Industry Yes | 86 | Minimum SAR severity | SAR meds/+ Pregnancy | Yes | • | | | | •
Kemp, 1987 | N. America Multiple | 2 weeks | NR NR | 209 | Minimum SAR severity | | No | • | | | • | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C2 Patient characteristics: oral selective antihistamine versus oral nonselective antihistamine

Author, Year | n | Drug, Dose/Day | Mean Age, years | Sex, % Female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Dockhorn, 1987 | 111 | Loratadine 10 mg | 31 Range: 12-61 | 21.3 | White: 92.6 Other: 7.4 | 16 Range: 2-48
| 109 | Clemastine 2 mg | 33 Range: 12-65 | 24.8 | White: 91.4 Other: 8.6 | 18 Range: 1-55
Harvey, 1996 | 43 | Cetirizine 5-10mg | 35.2 Range: 16.1-64.6 | 55.8 | White: 81.4 Black: 4.7 Hispanic: 11.6 Other: 2.3
| 43 | Chlorpheniramine 16mg | 34.4 Range: 16.4-68.3 | 60.5 | White: 74.4 Black: 9.3 Hispanic: 11.6 Other: 4.7
Kemp, 1987 | 108 | Loratadine 10 mg | 30 (11) Range :12-62 | 54.6 | Unspecified | 17 Range: 1-50 | TNSS: 7.5
| 101 | Clemastine 2 mg | 30 (12) Range: 12-64 | 47.5 | Unspecified | 16 Range: 1-42 | TNSS: 7.3

n = Patients randomized to comparator groups of interest. NSS = nasal symptom score; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a TNSS ranges from 0 to 12

Appendix Table C3 USPSTF quality assessment: oral selective antihistamine versus oral nonselective antihistamine

Author, Year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Dockhorn, 1987 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Harvey, 1996 | No | Uncertain | Yes | No | Yes | Yes | No | Poor
Kemp, 1987 | Yes | Uncertain | Uncertain | Yes | Yes | Yes | Yes | Fair

USPSTF = United States Preventive Services Task Force.

Appendix Table C4 Nasal symptom outcomes: change from baseline–oral selective antihistamine versus oral nonselective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | TNSS | p
Kemp, 1987 | Loratadine 10 mg | 108/108 | 2 | -2.8^a,b^ | NS
| Clemastine 2 mg | 101/101 | 2 | -2.5^a,b^

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NS= non-significant; TNSS = total nasal symptom score. TNSS ranges from 0 to 12.

a Values extracted from figures using Engauge Digitizer software.

b Values calculated by report author.

Appendix Table C5 Quality of life outcomes–oral selective antihistamine versus oral nonselective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline Mean | Change from Baseline | p
Harvey, 1996 | Loratadine 10 mg | 43/39 | 2 | RQLQ, 0 to 84 scale | 87.0 | -35.9^a^ | <0.05
| Clemastine 2 mg | 43/40 | 2 | | 89.2 | -23.0^a^

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; RQLQ = Rhinitis Quality of Life Questionnaire.

a Values calculated by report author.

## Oral Selective Antihistamine Versus Nasal Antihistamine

Appendix Table C6 Trial description: oral selective antihistamine versus nasal antihistamine

Author, Year | Location/Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Berger, 2003 | N. America Multiple | 2002 2 weeks | Industry NR | 219 | Minimum SAR severity and duration | SAR meds/+ Chronic asthma Pregnancy Infection Deformities | No | • | • | | • | •
Berger, 2006 | N. America Multiple | Spring 2005 2 weeks | Industry Industry | 360 | Minimum SAR severity and duration | SAR meds/Other meds Chronic asthma Pregnancy Infection Deformities | No | • | • | | • | •
Charpin, 1995 | Europe Multiple | 2 weeks | NR Industry | 136 | Minimum SAR severity and duration | SAR meds/+ Other meds Chronic asthma Pregnancy Infection Deformities | No | • | | | • | •
Corren, 2005 | N. America Multiple | 2004 2 weeks | NR Industry | 307 | Minimum SAR severity and duration | SAR meds/ Other meds Chronic asthma Pregnancy Infection Deformities | No | • | • | | • | •
Gambardella, 1993 | Europe | 6 weeks | NR NR | 30 | Minimum SAR duration | | No | | | | • | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C7 Patient characteristics: oral selective antihistamine versus nasal antihistamine

Author, Year | n | Drug, Dose/Day | Mean Age, years | Sex, % Female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Berger, 2003 | 111 | Desloratadine 5mg | 32.6 Range: 12-73 | 66.7 | White: 75.7 Black: 13.5 Asian: 0.9 Other: 9.9 | | C: 5.12 S: 3.57 R: 4.66 I: 4.31 TNSS: 17.67^b^
| 108 | Azelastine 4 puffs/nostril | 35.9 Range: 12-70 | 60.2 | White: 80.6 Black: 13.0 Asian: 2.8 Other: 3.7 | | C: 5.07 S: 3.60 R: 4.63 I: 4.40 TNSS: 17.70^b^
Berger, 2006 | 175 | Cetirizine 10mg | 34.3 Range: 12-74 | 56.0 | White: 77.7 Black: 8.6 Asian: 4.0 Other: 9.7 | 18.7 | TNSS: 18.7 (3.1)^b^
| 179 | Azelastine 4 puffs/nostril | 35.1 Range: 12-64 | 59.8 | White: 77.7 Black: 5.0 Asian: 5.0 Other: 12.3 | 18.4 | TNSS: 19.1 (3.2)^b^
Charpin, 1995 | 69 | Cetirizine 10mg | 30^c,d^
| 67 | Azelastine 2 puffs/nostril
Corren, 2005 | 155 | Cetirizine 10mg | 35.7 Range: 12-74 | 60.6 | White: 69.0 Black: 19.4 Asian: 3.9 Other: 7.7 | 20.0 Range: 2-58 | C: 5.27 (0.62) S: 3.98 (1.32) R: 4.61 (0.95) I: 4.64 (0.98) TNSS: 18.50 (2.85)^b^
| 152 | Azelastine 4 puffs/nostril | 35.6 Range: 12-74 | 63.2 | White: 70.4 Black: 19.1 Asian: 2.0 Other: 8.6 | 18.8 Range: 2-51 | C: 5.31 (0.62) S: 4.14 (1.25) R: 4.74 (0.97) I: 4.63 (1.14) TNSS: 18.82 (2.86)^b^
Gambardella, 1993 | 15 | Loratadine 10mg | 31^c,d^ Range: 18-55 | 16.7 | | Range: 2-31
| 15 | Azelastine 560 mcg

C = Congestion; I = itching; n = patients randomized to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 6 (severe symptoms) except as noted.

b TNSS is a sum of AM and PM scores ranging from 0 to 24.

c Values are medians.

d Overall demographic info provided only.

Appendix Table C8 USPSTF quality assessment: oral selective antihistamine versus nasal antihistamine

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Berger, 2003 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Berger, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Charpin, 1995 | No | Uncertain | Yes | Yes | Yes | Uncertain | No | Poor
Corren, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Gambardella, 1993 | No | Uncertain | Uncertain | Uncertain | Yes | Yes | No | Poor

USPSTF = United States Preventive Services Task Force.

Appendix Table C9 Nasal symptom outcomes: change from baseline–oral selective antihistamine versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS^a^ | p
Berger, 2003 | Desloratadine 5mg | 111/111 | 2 | -0.82 | NR | -0.78 | NR | -0.71 | NR | -0.78 | NR | -3.10 | NR
| Azelastine 4 puffs/nostril | 108/106 | 2 | -0.90 | NR | -1.00 | NR | -0.94 | NR | -1.03 | NR | -3.88 | NR
Berger, 2006 | Cetirizine 10mg | 175/175 | 2 | | 0.049 | | | | 0.010 | | | -3.9 (4.3) | 0.140
| Azelastine 4 puffs/nostril | 179/179 | 2 | | 0.049 | | | | 0.010 | | | -4.6 (4.2) | 0.140
Charpin, 1995 | Cetirizine 10mg | 69^b^ | 2 | | 0.002^d^ | | 0.044^d^ | | NS^d^ | | NS^d^
| Azelastine 2 puffs/nostril | 67^b^ | 2 | | 0.002^d^ | | 0.044^d^ | | NS^d^ | | NS^d^
Corren, 2005 | Cetirizine 10mg | 155/155 | 2 | -0.96 (1.26) | 0.187 | -1.00 (1.40) | 0.003 | -1.29 (1.36) | 0.065 | -1.09 (1.46) | 0.056 | -4.32 (4.66) | 0.015
| Azelastine 4 puffs/nostril | 152/151 | 2 | -1.13 (1.16) | 0.187 | -1.46 (1.39) | 0.003 | -1.58 (1.49) | 0.065 | -1.39 (1.45) | 0.056 | -5.56 (4.68) | 0.015

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; NS= non-significant; TNSS = total nasal symptom score.

Except as noted, entries for each symptom represents the mean change from baseline symptom score using a 0 (no symptom) to 6 (severe symptom) rating scale. Values are presented as mean (standard deviation) unless otherwise noted.

a TNSS is a sum of AM and PM scores ranging from 0 to 24.

b Only patients analyzed are reported.

c Symptoms scored on a 0-100 VAS.

d Linear regression of VAS scores over time.

Appendix Table C10 Quality of life outcomes–oral selective antihistamine versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline Mean | Change from Baseline | p
Berger, 2006 | Cetirizine 10mg | 175/175 | 2 | RQLQ | | -1.1 | 0.002
| Azelastine 4 puffs/nostril | 179/179 | 2 | | | -1.5 | 0.002
Charpin, 1995 | Cetirizine 10mg | 69^a^ | 2 | % Reporting excellent or good response to treatment | | 67.9^b^ | 0.87
| Azelastine 2 puffs/nostril | 67^a^ | 2 | | | 68.5^b^ | 0.87
Corren, 2005 | Cetirizine 10mg | 155/155 | 2 | RQLQ | 3.75 (1.03) | -1.11 (1.18) | 0.049
| Azelastine 4 puffs/nostril^b^ | 152/151 | 2 | | 3.69 (1.04) | -1.41 (1.25) | 0.049

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; RQLQ = Rhinitis Quality of Life Questionnaire.

Values are presented as mean (standard deviation) unless otherwise noted.

a Only patients analyzed are reported.

b Post-treatment values.

c Equivalent to 4 puffs.

## Oral Selective Antihistamine Versus Intranasal Corticosteroid

Appendix Table C11 Trial description: oral selective antihistamine versus intranasal corticosteroid

Author, Year | Location/Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Andrews, 2009 (Trial 1) | N. America Multi-center | 2006 2 weeks | Industry Yes | 623 | Minimum SAR severity and duration | SAR meds/+ Chronic asthma Pregnancy Infection Deformities | No | • | • | • | • | •
Andrews, 2009 (Trial 2) | N. America Multi-center | 2007 2 weeks | Industry Yes | 451 | Minimum SAR severity and duration | SAR meds/+ Other meds Chronic asthma Pregnancy Infection Deformities | No | • | • | • | • | •
Anolik, 2008 | N. America Multi-center | March 1995 15 days | NR Yes | 526 | Minimum SAR severity and duration | Chronic asthma Immunotherapy Infection Deformities | No | • | • | • | • | •
Bernstein, 2004 | N. America Multi-center | 4 weeks | Industry Yes | 316 | Minimum SAR severity and duration | SAR meds/NR | No | • | • | | • | •
Condemi, 2000 | N. America Multi-center | 4 weeks | Industry Yes | 351 | Minimum SAR severity and duration | SAR meds/+ Other meds Pregnancy Infection Deformities | No | • | • | • | • | •
Gawchik, 1997 | N. America Multi-center | 4 weeks | Industry Yes | 305 | Minimum SAR severity and duration | SAR meds/+ Other meds Immunotherapy Pregnancy Infection | | • | • | • | • | •
Gehanno, 1997 | Europe Multi-center | March 1991 4 weeks | Industry Yes | 114 | Minimum SAR severity | SAR meds/+ Pregnancy | Yes | • | | | • | •
Jordana, 1996 | N. America Multi-center | 4 weeks | Industry Yes | 242 | | SAR meds/- Pregnancy Infection Deformities | Yes | • | • | • | • | •
Kaszuba, 2001 | N. America Single center | August 1999 4 weeks | Industry, NIH No | 88 | Minimum SAR duration | SAR meds/+ Pregnancy Deformities | No | • | | •
Lu, 2009 (Trial 1) | N. America Multi-center | April 1998 2 weeks | Industry Yes | 289 | Minimum SAR severity and duration | | No | • | • | | • | •
Ratner, 1998 | N. America Multi-center | 2 weeks | Industry Yes | 450 | Minimum SAR severity and duration | SAR meds/+ Pregnancy Infection Deformities | No | • | • | | • | •
Schoenwetter, 1995 | N. America Multi-center | 4 weeks | Industry Yes | 298 | Minimum SAR severity and duration | SAR meds/+ Other meds Pregnancy Infection Deformities | No | • | • | • | • | •
Vervloet, 1997 | Europe Multi-center | 3 weeks | Industry Yes | 238 | Minimum SAR severity | SAR meds/+ Immunotherapy Pregnancy Deformities | Yes | • | | • | • | •

N = Patients randomized to comparator groups of interest; NIH = National Institutes of Health; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C12 Patient characteristics: oral selective antihistamine versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | n | Mean Age, years | Sex, % Female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Andrews, 2009 (Trial 1) | Fexofenadrine 180 mg | 311 | 39.6 (14.63) | 64 | White: 92 Black: 3 Other: 5 | ≥2 to <5: 11% ≥5 to <10: 22% ≥10: 67% | TNSS: 9.8 (SE: 0.09)
| Fluticasone furoate 110 mcg | 312 | 37.8 (13.95) | 67 | White: 86 Black: 8 Other: 6 | ≥2 to <5: 14% ≥5 to <10: 18% ≥10: 67% | TNSS: 9.8 (SE: 0.09)
Andrews, 2009 (Trial 2) | Fexofenadrine 180 mg | 227 | 34.3 (13.66) | 59 | White: 80 Black: 19 Other: 2 | ≥2-<5: 10% ≥5-<10: 19% ≥10: 71% | TNSS: 9.9 (SE: 0.11)
| Fluticasone furoate 110 mcg | 224 | 34.0 (13.55) | 68 | White: 84 Black: 13 Other: 3 | ≥2-<5: 8% ≥5-<10: 21% ≥10: 71% | TNSS: 9.7 (SE: 0.10)
Anolik, 2008 | Loratadine 10 mg | 176 | 25 (Range: 12-65) | 50.3 | Unspecified | 14 (Range: 2-60) | C: 2.3 S: 1.7 R: 2.1 I: 1.9 TNSS: 7.9 (2.2)
| Mometasone furoate 200 mcg | 169 | 26 (Range: 12-71) | 50.6 | Unspecified | 13 (Range: 2-56) | C: 2.2 S: 1.7 R: 2.1 I: 1.7 TNSS: 7.8 ( 2.5)
Bernstein, 2004 | Loratadine 10 mg | 158 | 80% of patients were between 18 and 64 years old^b^ | 58-62^b^ | White: 80-89^b^ | | C: 78.3^c^ (SE: 1.1)
| Fluticasone propionate 200 mcg | 158 | | | | | C: 79.0^c^ (SE: 1.1)
Condemi, 2000 | Loratadine 10 mg | 176 | 32 (Range: 12-69)^b^ | 55^c^ | White: 90^b^ | | C: 2.3 S: 2.1 R: 2.1 I: 2.0 TNSS: 8.4
| Triamcinolone acetonide 220 mcg | 175 | | | | | C: 2.2 S: 2.0 R: 2.0 I: 2.0 TNSS: 8.2
Gawchik, 1997 | Loratadine 10 mg | 153 | 32.6 (12.0) | 58 | White: 90 Black: 8 Hispanic: 1 Asian: <1 | Mean: 17.5 (11.2)
| Triamcinolone acetonide 220 mcg | 152 | 33.7 (13.0) | 57 | White: 91 Black: 6 Hispanic: <1 Asian: 2 | Mean: 19.1 (12.9)
Gehanno, 1997 | Loratadine 10 mg | 57 | 41.0 (Range: 13-80) | 58 | Unspecified | <2: 18% 2-5: 49% 6-10: 9% >10: 25%
| Fluticasone propionate 200 mcg | 57 | 37.0 (Range: 15-70) | 53 | Unspecified | <2: 16% 2-5: 44% 6-10: 16% >10: 25%
Jordana, 1996 | Loratadine 10 mg | 119 | Range: 12-17 | 40.3 | Unspecified
| Fluticasone propionate 200 mcg | 121 | Range: 12-17 | 47.1 | Unspecified
Kaszuba, 2001 | Loratadine 10 mg^d^ | 44 | 30.0^e^ (Range: 19-44) | 43 | White: 57
| Fluticasone propionate 200 mcg^d^ | 44 | 27.5^e^ (Range: 18-48) | 52 | White: 64
Lu, 2009 (Trial 1) | Loratadine 10 mg | 116 | 34.8 (12.4) | 64.7 | White: 79.3 Black: 6.9 Hispanic: 8.6 Other: 5.2 | 18.1 (11.0) | TNSS: 2.11
| Beclomethasone dipropionate 400 mcg^f^ | 173 | 34.1 (13.3) | 61.3 | White: 79.2 Black: 8.1 Hispanic: 8.1 Other: 4.6 | 17.9 (12.2) | TNSS: 2.03
Ratner, 1998 | Loratadine 10 mg | 150 | 40.1 (Range: 15-70) | 54 | White: 73 Hispanic: 19 Other: 8 | | TNSS: 300^c,g^
| Fluticasone propionate 200 mcg | 150 | 40.7 (Range: 13-80) | 55 | White: 78 Hispanic: 15 Other: 7 | | TNSS: 290^c,g^
Schoenwetter, 1995 | Loratadine 10 mg | 149 | 31.2 (11.3) | 57 | White: 89 Black: 5 Hispanic: 2 Other: <1 | 17.2 ( 11.2) | C: 2.07 S: 1.93 R: 1.85 I: 1.95 TNSS: 7.80^h^
| Triamcinolone acetonide 220 mcg | 149 | 31.4 (11.5) | 58 | White: 91 Black: 4 Hispanic: 2 Other: 3 | 19.1 ( 11.6) | C: 2.12 S: 1.94 R: 1.99 I: 1.90 TNSS: 7.95^h^
Vervloet, 1997 | Cetirizine 10 mg | 118 | 30 (Range: 12-75) | 49.2 | Unspecified | <1: 2.54% 1-3: 13.56% 4-8: 38.14% >8: 45.76% | TNSS: 9.36^i^ (2.17)
| Fluticasone propionate 200 mcg | 120 | 28 (Range: 12-71) | 47.1 | Unspecified | <1: 1.68% 1-3: 18.49% 4-8: 31.93% >8: 47.9% | TNSS: 9.23^i^ (2.02)

C = congestion; I = itching; n = patients randomized to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; SE = standard error; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual nasal symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) except as noted. TNSS ranges from 0 to 12.

b Overall demographic info provided only.

c Individual symptoms rated on a visual analog scale from 0 to 100. TNSS ranges from 0 to 400.

d As-needed (prn) dosing.

e Values are medians.

f Twice daily (bid) dosing.

g Values extracted from figures using Engauge Digitizer software.

h Values calculated by report author.

i TNSS is the sum of 5 individual symptom scores rated on a scale from 0 (none) to 3 (severe): congestion when waking, daytime congestion, rhinorrhea, sneezing, and nasal itch. TNSS ranges from 0 to 15.

Appendix Table C13 USPSTF quality assessment: oral selective antihistamine versus intranasal corticosteroid

Author, Year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Andrews, 2009 (Trial 1) | Yes | Yes | Yes | Yes | Uncertain | Yes | Yes | Fair
Andrews, 2009 (Trial 2) | Yes | Yes | Yes | Yes | Uncertain | Yes | Yes | Fair
Anolik, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Bernstein, 2004 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Condemi, 2000 | No | Uncertain | Yes | Yes | Yes | Yes | Yes | Poor
Gawchik, 1997 | No | Uncertain | Yes | Yes | Yes | Yes | No | Poor
Gehanno, 1997 | No | Uncertain | Yes | Yes | Yes | Yes | Yes | Poor
Jordana, 1996 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kaszuba, 2001 | No | Uncertain | Yes | No | Yes | Uncertain | No | Poor
Lu, 2009 (Trial 1) | Yes | Yes | Yes | Uncertain | Yes | Yes | No | Poor
Ratner, 1998 | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Fair
Schoenwetter, 1995 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Vervloet, 1997 | Yes | Yes | Yes | Yes | Yes | No | No | Poor

USPSTF = United States Preventive Services Task Force

Appendix Table C14 Nasal symptom outcomes: change from baseline–oral selective antihistamine versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N/n | Time, Weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS | p
Andrews, 2009 (Trial 1) | Fexofenadrine 180 mg | 311/311 | 2 | | | | | | | | | | <0.001
Andrews, 2009 (Trial 1) | Fluticasone furoate 110 mcg | 312/312 | 2 | | | | | | | | | | <0.001
Andrews, 2009 (Trial 2) | Fexofenadrine 180 mg | 227/227 | 2 | | | | | | | | | | <0.001
Andrews, 2009 (Trial 2) | Fluticasone furoate 110 mcg | 224/244 | 2 | | | | | | | | | | <0.001
Anolik, 2008 | Loratadine 10 mg | 181/175 | 2.1 | -0.4 | NS | -0.4 | NS | -0.6 | NS | -0.6 | NS | -1.9 (2.2) | NS
Anolik, 2008 | Mometasone furoate 200 mcg | 176/166 | 2.1 | -0.7 | NS | -0.7 | NS | -0.7 | NS | -0.6 | NS | -2.7 (2.5) | NS
Gawchik, 1997 | Loratadine 10 mg | 153/137 | 2 | | | | | | | | | -3.6^a,b^ | <0.05
Gawchik, 1997 | Triamcinolone acetonide 220 mcg | 152/142 | 2 | | | | | | | | | -4.6^a,b^ | <0.05
Lu, 2009 (Trial 1) | Loratadine 10 mg | 116/115 | 2 | | | | | | | | | -0.53 (95% CI -0.63, -0.42) | NR
Lu, 2009 (Trial 1) | Beclomethasone dipropionate 400 mcg^c^ | 173/172 | 2 | | | | | | | | | -0.70 (95% CI -0.78, -0.61) | NR
Ratner, 1998 | Loratadine 10 mg | 150/150 | 2 | | | | | | | | | -90^a,d^ | <0.001
Ratner, 1998 | Fluticasone propionate 200 mcg | 150/150 | 2 | | | | | | | | | -150^a,d^ | <0.001
Gawchik, 1997 | Loratadine 10 mg | 153/137 | 3 | | | | | | | | | -4.1^a,b^ | NR
Gawchik, 1997 | Triamcinolone acetonide 220 mcg | 152/142 | 3 | | | | | | | | | -5.3^a,b^
Vervloet, 1997 | Cetirizine 10 mg | 118/118 | 3 | | | | | | | | | -4.96^e^ | <0.001
Vervloet, 1997 | Fluticasone propionate 200 mcg | 120/119 | 3 | | | | | | | | | -7.13^e^ | <0.001
Bernstein, 2004 | Loratadine 10 mg | 158/158 | 4 | -25.0^d^ (1.9)^f^ | ≤0.003
Bernstein, 2004 | Fluticasone propionate 200 mcg | 158/158 | 4 | -35.3^d^ (1.9)^f^ | ≤0.003
Condemi, 2000 | Loratadine 10 mg | 176/174 | 4 | -0.8 (1.0) | <0.05 | -0.9 (1.0) | NS | -0.9 (0.9) | <0.05 | -0.9 (0.9) | <0.05 | -3.6 (3.2) | <0.05
Condemi, 2000 | Triamcinolone acetonide 220 mcg | 175/174 | 4 | -1.1 (0.9) | <0.05 | -1.1 (0.9) | NS | -1.2 (0.9) | <0.05 | -1.1 (0.8) | <0.05 | -4.4 (2.9) | <0.05
Gawchik, 1997 | Loratadine 10 mg | 153/137 | 4 | | <0.02 | | NS | | <0.02 | | <0.02 | -4.4^a,b^ | <0.02
Gawchik, 1997 | Triamcinolone acetonide 220 mcg | 152/142 | 4 | | <0.02 | | NS | | <0.02 | | <0.02 | -5.2^a,b^ | <0.02
Gehanno, 1997 | Loratadine 10 mg | 57/57 | 4 | | | | | | | | | | 0.009
Gehanno, 1997 | Fluticasone propionate 200 mcg | 57/57 | 4 | | | | | | | | | | 0.009
Jordana, 1996 | Loratadine 10 mg | 119/119 | 4 | | <0.001 | | <0.001 | | 0.001 | | 0.011
Jordana, 1996 | Fluticasone propionate 200 mcg | 121/121 | 4 | | <0.001 | | <0.001 | | 0.001 | | 0.011
Kaszuba, 2001 | Loratadine 10 mg g | 44^h^ | 4 | | 0.02 | | 0.02 | | 0.009
Kaszuba, 2001 | Fluticasone propionate 200 mcg^g^ | 44^h^ | 4 | | 0.02 | | 0.02 | | 0.009
Schoenwetter, 1995 | Loratadine 10 mg | 149/140 | 4 | -0.43 (0.70) | ≤0.001 | -0.5 (0.72) | ≤0.001 | -0.68 (0.71) | ≤0.001 | -0.76 (0.70) | ≤0.001
Schoenwetter, 1995 | Triamcinolone acetonide 220 mcg | 149/134 | 4 | -0.89 (0.79) | ≤0.001 | -1.05 (0.70) | ≤0.001 | -1.13 (0.80) | ≤0.001 | -1.05 (0.78) | ≤0.001

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; NS = non- significant; TNSS = total nasal symptom score.

Except as noted, entries for each symptom represent the mean change from baseline symptom score using a 0 (no symptom) to 3 (severe symptom) rating scale. TNSS ranges from 0 to 12. Values are presented as mean (standard deviation) unless otherwise noted.

a Values extracted from figures using Engauge Digitizer software.

b Change in symptom scores calculated using end of treatment scores rather than scores averaged over the treatment interval.

c Twice daily (BID) dosing.

d Individual symptom scores rated on a visual analog scale from 0 (no symptom) to 100 (severe symptom): congestion, rhinorrhea, sneezing, and nasal itch. Maximum TNSS is 400.

e TNSS is the sum of 5 individual symptom scores rated on a scale from 0 (no symptom) to 3 (severe symptom): congestion when waking, congestion the rest of the day, rhinorrhea, sneezing, and nasal itch. TNSS ranges from 0 to 15.

f Standard error.

g As needed (prn) dosing.

h Only patients randomized are reported.

Appendix Table C15 Eye symptom outcomes–oral selective antihistamine versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N/n | Time, Weeks | Outcome | Baseline Mean | Change from Baseline | p
Andrews, 2009 (Trial 1) | Fexofenadrine 180 mg | 311/311 | 2 | TOSS (scale 0-9) | 7.0 (0.08)^a^ | | 0.106
Andrews, 2009 (Trial 1) | Fluticasone furoate 110 mcg | 312/312 | 2 | | 6.9 (0.08)^a^
Andrews, 2009 (Trial 2) | Fexofenadrine 180 mg | 227/227 | 2 | TOSS (scale 0-9) | 7.0 (0.10)^a^ | | 0.002
Andrews, 2009 (Trial 2) | Fluticasone furoate 110 mcg | 224/224 | 2 | | 6.8 (0.10)^a^
Anolik, 2008 | Loratadine 10 mg | 181/175 | 2 | Tearing | | | 0.04^b^
Anolik, 2008 | Mometasone furoate 200 mcg | 176/166 | 2
Gawchik, 1997 | Loratadine 10 mg | 153/137 | 2 | Symptoms undefined | | | NS
| Triamcinolone acetonide 220 mcg | 152/142 | 2
Bernstein, 2004 | Loratadine 10 mg | 158/158 | 4 | TOSS (scale 0-300) | 204.3^c^ (3.8)^a^ | -72.5^c^ (5.4)^a^ | 0.028
Bernstein, 2004 | Fluticasone propionate 200 mcg | 158/158 | 4 | | 209.4^c^ (3.8)^a^ | -88.7^c^ (5.3)^a^
Condemi, 2000 | Loratadine 10 mg | 176/174 | 4 | TOSS (scale 0-9) | 1.9 | -0.9 (1.0) | NS
Condemi, 2000 | Triamcinolone acetonide 220 mcg | 175/174 | 4 | | 1.9 | -0.9 (0.9)
Gawchik, 1997 | Loratadine 10 mg | 153/137 | 4 | Symptoms undefined | | | <0.02
Gawchik, 1997 | Triamcinolone acetonide 220 mcg | 152/142 | 4
Schoenwetter, 1995 | Loratadine 10 mg | 149/140 | 4 | Symptoms undefined | 1.75 | -0.69 (0.69) | NS
Schoenwetter, 1995 | Triamcinolone acetonide 220 mcg | 149/134 | 4 | | 1.75 | -0.80 (0.78)

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NS = not significant; TOSS = total ocular symptom score.

TOSS is the sum of scores for 3 ocular symptoms (itching, tearing, and redness). Values are presented as mean (standard deviation) unless otherwise noted.

a Standard error

b Anolik, 2008 assessed ocular itching, tearing, and redness. Baseline and change from baseline values were not provided. One statistically significant result was reported as shown. For ocular itching and redness, INCS was not statistically superior to selective oral antihistamine. P-values not reported.

c TOSS is the sum of 3 individual eye symptom scores rated on a visual analog scale from 0 (no symptom) to 100 (severe symptom): itching, tearing, and redness. TOSS ranges from 0 to 300.

Appendix Table C16 Quality of life outcomes–oral selective antihistamine versus intranasal corticosteroids

Author, Year | Drug, Dose/Day | N/n | Time, Weeks | Outcome | Baseline Mean | Change from Baseline | p
Andrews, 2009 (Trial 1) | Fexofenadrine 180 mg | 311/311 | 2 | Nocturnal RQLQ | 4.3 (SE: 0.06) | | <0.001
Andrews, 2009 (Trial 1) | Fluticasone furoate 110 mcg | 312/312 | | | 4.2 (SE: 0.05) | | <0.001
Andrews, 2009 (Trial 2) | Fexofenadrine 180 mg | 227/227 | 2 | Nocturnal RQLQ | 4.2 (SE: 0.07) | | <0.001
Andrews, 2009 (Trial 2) | Fluticasone furoate 110 mcg | 224/224 | | | 4.1 (SE: 0.07) | | <0.001
Condemi, 2000 | Loratadine 10 mg | 176^a^ | 2 | RQLQ | 3.79 (0.89) | -1.66^b^ | <0.05
Condemi, 2000 | Triamcinolone acetonide 220 mcg | 175^a^ | | | 3.70 (0.89) | -1.9^b^
Kaszuba, 2001 | Loratadine 10 mg^c^ | 44^d^ | 2 | RQLQ | 2.0^b,e^ | 0.0^f^ | <0.01
Kaszuba, 2001 | Fluticasone propionate 200 mcg^c^ | 44^d^ | | | 2.4^b,e^ | -1.0^f^
Ratner, 1998 | Loratadine 10 mg | 150/150 | 2 | RQLQ | 4.1 (0.1) | -1.3 (0.1) | <0.001
Ratner, 1998 | Fluticasone propionate 200 mcg | 150/150 | | | 4.1 (0.1) | -2.2 (0.1)
Ratner, 1998 | Loratadine 10 mg | 150/150 | 2 | % signif, mod, or mild improve^g^ | -- | 63.9^b^ | <0.001^h^
Ratner, 1998 | Fluticasone propionate 200 mcg | 150/150 | | | | 88.7^b^
Vervloet, 1997 | Cetirizine 10 mg | 118^d^ | 3 | PGA: scale 0-100^i^ | 61.45 (22.75) | -31 (31) | <0.001
Vervloet, 1997 | Fluticasone propionate 200 mcg | 120^d^ | | | 63.50 (21.15) | -51 (26)
Vervloet, 1997 | Cetirizine 10 mg | 118^d^ | | % v. effective/effective^j^ | -- | 64.3 | <0.001
Vervloet, 1997 | Fluticasone propionate 200 mcg | 120^d^ | | | | 89.5
Bernstein, 2004 | Loratadine 10 mg | 158^a^ | 4 | RQLQ | | | <0.05
Bernstein, 2004 | Fluticasone propionate 200 mcg | 158^a^
Bernstein, 2004 | Loratadine 10 mg | 158^a^ | 4 | % signif, mod, or mild improve^g^ | -- | 64 | <0.001
Bernstein, 2004 | Fluticasone propionate 200 mcg | 158^a^ | | | | 82
Condemi, 2000 | Loratadine 10 mg | 176^a^ | 4 | RQLQ | 3.79 (0.89) | -1.97^b^ | <0.05
Condemi, 2000 | Triamcinolone acetonide 220 mcg | 175^a^ | | | 3.70 (0.89) | -2.22^b^
Gehanno, 1997 | Loratadine 10 mg | 57/57 | 4 | RQLQ | | | <0.05
Gehanno, 1997 | Fluticasone propionate 200 mcg | 57/57
Gehanno, 1997 | Loratadine 10 mg | 57/57 | 4 | % v. effective/effective^j^ | -- | 69.2 | NS
Gehanno, 1997 | Fluticasone propionate 200 mcg | 57/57 | | | | 79.2
Kaszuba, 2001 | Loratadine 10 mg^c^ | 44^d^ | 4 | RQLQ | 2.0^b,e^ | -0.3^f^ | <0.05
Kaszuba, 2001 | Fluticasone propionate 200 mcg^c^ | 44^d^ | | | 2.4^b,e^ | -1.2^f^

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NS = non-significant; PGA = patient global assessment; RQLQ = Rhinitis Quality of Life Questionnaire; SE = standard error.

Values are presented as mean (standard deviation) unless otherwise noted.

a n analyzed not reported.

b Values extracted from figures using Engauge Digitizer software.

c As needed (prn) dosing.

d Only patients randomized reported.

e Median.

f Values calculated by report author.

g 7-point scale: significant, moderate, or mild improvement; no change; mild, moderate, or significant worsening.

h P-value calculated by report author using 2×2 chi-square at mild improvement cut point.

i Discomfort due to rhinitis was rated on a visual analog scale from 0 (no discomfort) to 100 (worst discomfort ever experienced).

j 4-point scale: very effective, effective, slightly effective, ineffective.

## Oral Selective Antihistamine Versus Oral Decongestant

Appendix Table C17 Trial description: oral selective antihistamine versus oral decongestant

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria | Rescue Medication Use | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Bronsky, 1995 | N. America Multiple | Fall 1989 2 weeks | Industry Yes | 437 | Minimum SAR severity and duration | SAR meds Other meds Chronic asthma Pregnancy Infection | No | • | • | • | • | •
Chervinsky, 2005 | N. America Multiple | 2 weeks | NR Yes | 436 | Minimum SAR severity and duration | SAR meds Pregnancy Infection | No | • | • | • | • | •
Grosclaude, 1997 | Europe Multiple | March1992 2 weeks | NR Yes | 454 | Minimum SAR severity and duration | SAR meds Other meds Pregnancy Infection Deformities | Yes | • | | • | • | •
Grubbe, 2009 | N. America Multiple | 2.1 weeks | Industry Yes | 398 | Minimum SAR severity and duration | SAR meds Chronic asthma Pregnancy Infection Deformities | No | • | • | • | • | •
Pleskow, 2005 | N. America Multiple | 2000 2 weeks | Industry Yes | 749 | Minimum SAR severity and duration | SAR meds Pregnancy Infection Deformities | No | • | • | • | • | •
Schenkel, 2002 | N.America Multiple | 2.1 weeks | Industry NR | 682 | Minimum SAR duration | SAR meds Chronic asthma Pregnancy | No | • | • | | • | •
Sussman, 1999 | N.America Multiple | 2.6 weeks | Industry Yes | 436 | Minimum SAR severity | SAR meds Pregnancy Infection | No | • | • | • | • | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C18 Patient characteristics: oral selective antihistamine versus oral decongestant

Author, Year | Drug, Dose/Day | n | Mean Age, years | Sex, % female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Bronsky., 1995 | Loratadine 10 mg | 217 | Median: 30 Range: 12-60 | 57.5 | White: 87.3 Black: 4.2 Other: 8.5 | Median: 15 Range: 1-50
| Pseudoephedrine 240 mg | 220 | Median: 28 Range: 12-60 | 51.2 | White: 92.9 Black: 1.9 Other: 5.2 | Median: 15 Range: <1-50
Chervinsky, 2005 | Desloratadine 5 mg | 214 | 37 | 69 | Unspecified | 19 | C: 2.56
| Pseudoephedrine 240 mg | 222 | 36 | 65 | Unspecified | 19 | C: 2.56
Grosclaude, 1997 | Cetirizine 10 mg | 231 | 32 Range: 12-66 | 52 | Unspecified | 8 | C: 2.28 R: 2.07 S: 2.02 I: 1.76
| Pseudoephedrine 240 mg | 223 | 34 Range: 12-65 | 51 | Unspecified | 8 | C: 2.24 R: 2.00 S: 1.99 I: 1.79
Grubbe, 2009 | Desloratadine 5 mg | 198 | 37 Range: 12-76 | 65.2 | White: 77 Black: 13 Hispanic: 7 Asian: 2 Other: 2 | 17.9 Range: 2-56 | C: 2.50
| Pseudoephedrine 240 mg | 200 | 35 Range: 12-68 | 62.0 | White: 82 Black: 10 Hispanic: 4 Asian: 3 Other: 2.5 | 18.0 Range: 2-54 | C: 2.46
Pleskow, 2005 | Desloratadine 5 mg | 372 | 35 Range: 12-76 | 65.9 | White: 80 Black: 12 Hispanic: 7 Asian: <1 Other: 0 | 18.0 Range: 2-55
| Pseudoephedrine 240 mg | 377 | 36 Range: 12-70 | 65.5 | White: 78 Black: 10 Hispanic: 9 Asian: 1 Other: 2 | 17.9 Range: 2-50
Schenke, 2002 | Desloratadine 5 mg | 340 | 34.8 | 60 | Unspecified | 18.3 | C: 2.57
| Pseudoephedrine 240 mg | 342 | 34.2 | 65 | Unspecified | 17.6 | C: 2.54
Sussman, 1999 | Fexofenadrine 120 mg | 218 | 34.9 ( 12.35) Range: 12-64 | 56.9 | White: 85.3 Black: 6.0 Asian: 8.3 Other: 0.5 | 15.2 (9.79) Range: 2.0-46.2 | C: 2.36 (SE 0.03)*
| Pseudoephedrine 240 mg | 218 | 31.7 (11.12) Range: 12-66 | 58.7 | White: 89.0 Black: 4.1 Asian: 5.5 Other: 1.4 | 15.9 (10.06) Range: 1.0-46.0 | C: 2.34 (SE 0.03)

C = congestion; I = itching; n = patients randomized to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; SE = standard error; TNSS = total nasal symptom score.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) in all cases except Sussman 1999, where the maximum was 4.

Appendix Table C19 USPSTF quality assessment: oral selective antihistamine versus oral decongestant

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Bronsky, 1995 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Chervinsky, 2005 | Yes | Uncertain | Yes | Yes | Yes | Yes | No | Poor
Grosclaude, 1997 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Grubbe, 2009 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Pleskow, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Schenkel, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Sussman, 1999 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

USPSTF = United States Preventive Services Task Force.

Appendix Table C20 Nasal symptom outcomes: change from baseline–oral selective antihistamine versus oral decongestant

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion^a^ | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS | p
Bronsky, 1995 | Loratadine 10 mg | 217/212 | 2 | -0.5 | NR | | | | | | | -2.3 | NR
| Pseudoephedrine 240 mg | 220/211 | | -0.6 | | | | | | | | -2.4
Chervinsky, 2005 | Desloratadine 5 mg | 214/200 | 2 | -0.73 | NR
| Pseudoephedrine 240 mg | 222/204 | | -0.83
Grosclaude, 1997 | Cetirizine 10 mg | 231/231 | 2 | -0.85^b^ | | -0.96^b^ | | -1.11^b^ | | -0.86^b^
| Pseudoephedrine 240 mg | 223/223 | | -1.02^b^ | | -0.75^b^ | | -0.79^b^ | | -0.73^b^
Grubbe, 2009 | Desloratadine 5 mg | 198^c^ | 2 | -0.66
| Pseudoephedrine 240 mg | 200^c^ | | -0.75
Pleskow, 2005 | Desloratadine 5 mg | 372^c^ | 2 | -0.74 | 0.53
| Pseudoephedrine 240 mg | 377^c^ | | -0.78
Schenkel, 2002 | Desloratadine 5 mg | 340/340 | 2 | 0.65 | NS
| Pseudoephedrine 240 mg | 342/342 | | 0.70
Sussman, 1999 | Fexofenadrine 120 mg | 218/218 | 2.6 | -0.4^d^ | NS | -0.4^d^ | | -0.5^d^
| Pseudoephedrine 240 mg | 218/218 | | -0.5^d^ | | -0.3^d^ | | -0.3^d^

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported, NS= non-significant; TNSS = total nasal symptom score.

a Mean change from baseline over the entire treatment duration.

b Calculated by author using pre/post data.

c Only patient randomized are reported.

d Values extracted from figures using Engauge Digitizer Software.

Appendix Table C21 Eye symptom outcomes–oral selective antihistamine versus oral decongestant

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline | P
Grosclaude, 1997 | Cetirizine 10 mg | 231/231 | 2 | Itching eyes | 1.83 | -1.02 a,c | NR
| Pseudoephedrine 240 mg | 223/223 | | | 1.75 | -0.81 a, c
Sussman, 1999 | Fexofenadrine 120 mg | 218/218 | 2.6 | Itchy, watery, red eyes | NR | -0.5 b,c | NR
| Pseudoephedrine 240 mg | 218/218 | | | NR | -0.4 b,c

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported.

a 4-point scale: 0, absent; 1, mild; 2, moderate; 3, severe.

b 5-point scale: 0, absent; 1, mild; 2, moderate; 3, severe; 4, very severe.

c Values obtained using Engauge Digitizer Software.

Appendix Table C22 Quality of life outcomes–oral selective antihistamine versus oral decongestant

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | End of treatment | P
Bronsky, 1995 | Loratadine 10 mg | 217/212 | 2 | % Patients reporting good or excellent response to treatment^a^ | | 47^b^ | 0.25^d^
| Pseudoephedrine 240 mg | 220/211 | | | | 52^c^

N/n = number of patients randomized to comparator groups of interest/number of patients analyzed.

a 5 point scale: 1, excellent; 2, good; 3, fair; 4, poor; 5, treatment failure.

b 95/203

c 106/202

d P-value calculated by report author.

## Oral Selective Antihistamine Versus Oral Leukotriene Receptor Antagonist

Appendix Table C23 Trial description: oral selective antihistamine versus leukotriene receptor antagonist

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Dx | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Baena-Cagnani, 2003 | N. America Multiple | 4 weeks | NR NR | 622 | Minimum SAR duration | SAR meds/NR Other meds Pregnancy Infection Deformities | Yes | • | • | | • | •
Lombardo, 2006 | Europe Single | 4 weeks | NR NR | 200 | Minimum SAR severity and duration | SAR meds/NR Other meds Immunotherapytherapy Pregnancy Infection Deformities | No | • | • | | • | •
Lu, 2009 (Trial 1) | N. America Multiple | April 1998 2 weeks | Industry Yes | 228 | Minimum SAR severity and duration | | No | • | • | | • | •
Lu, 2009 (Trial 2) | N. America Multiple | April 1998 2 weeks | Industry Yes | 267 | Minimum SAR severity and duration | | No | • | • | | • | •
Meltzer, 2000 | N. America Multiple | March1997 2 weeks | Industry Yes | 187 | Minimum SAR severity and duration | SAR meds/- Other meds Pregnancy Infection | No | • | • | • | • | •
Nayak, 2002 | N. America Multiple | September 1999 2 weeks | Industry Yes | 456 | Minimum SAR severity and duration | SAR meds/- Other meds Pregnancy Infection Deformities | No | • | • | • | • | •
Philip, 2002 | N. America Multiple | 2000 2 weeks | Industry Yes | 950 | Minimum SAR severity and duration | SAR meds/NR Pregnancy Infection Deformities | No | • | • | • | • | •
van Adelsberg, 2003 (Trial 1) | N. America Multiple | 2001 2 weeks | Industry Yes | 693 | Minimum SAR severity and duration | SAR meds/NR Other meds Infection Deformities | No | • | • | • | • | •
van Adelsberg, 2003 (Trial 2) | N. America Multiple | 4 weeks | Industry NR | 628 | Minimum SAR severity and duration | SAR meds/NR Other meds Infection | No | • | • | • | • | •

N = patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C24 Patient characteristics: oral selective antihistamine versus leukotriene receptor antagonist

Author, Year | n | Drug Dose/Day | Mean Age, years | Sex, % female | Race, % | Disease duration, Years | Mean Baseline NSS^a^
Baena-Cagnani, 2003 | 311 | Desloratadine 5mg | 32.3 Range: 15-75 | 63 | White: 82 | 16.2
| 311 | Montelukast 10mg | 33.7 Range: 15-71 | 61 | White: 79 | 17.2
Lombardo, 2006 | 96 | Levocetirizine 5mg | 42 (13) Range: 18-58 | 39.6 | Unspecified | 16 (12) | TNSS: 2.12 (0.38)
| 104 | Montelukast 10mg | Range: 20-56 | 43.3 | Unspecified | 14 (12) | TNSS: 2.02 (0.39)
Lu, 2009 (Trial 1) | 116 | Loratadine 10mg | 34.8 (12.4) | 64.7 | White: 79.3 Black: 6.9 Hispanic: 8.6 Other: 5.2 | 18.1 (11.0) | TNSS: 2.11
| 112 | Montelukast 10mg | 35.6 (13.1) | 62.5 | White: 79.5 Black: 5.4 Hispanic: 8.9 Other: 6.3 | 18.8 (10.7) | TNSS: 2.06
Lu, 2009 (Trial 2) | 164 | Loratadine 10mg | 30.6(10.9) | 60.4 | White: 89.0 Black: 7.9 Hispanic: 2.4 Other: 0.6 | 17.3 (10.3) | TNSS: 1.97
| 103 | Montelukast 10mg | 31.1(13.1) | 62.1 | White: 89.3 Black: 5.8 Hispanic: 1.9 Other: 2.9 | 19.3 (11.2) | TNSS: 2.03
Meltzer, 2000 | 92 | Loratadine 10mg | Median: 34.5 Range: 15-66 | 53.3 | Unspecified | 19 (13) | TNSS: 2.07 (0.41)
| 95 | Montelukast 10mg | Median: 33 Range: 15-71 | 57.9 | Unspecified | 18 (13) | TNSS: 2.12 (0.38)
Nayak, 2002 | 155 | Loratadine 10mg | 35 (11) Range: 15-65 | 66 | White: 83 Black: 10 Hispanic: 4 Asian: 1 Other: 2 | 18 (13) Range: 2-60 | TNSS: 2.06 (0.39)
| 301 | Montelukast 10mg | 37 (13) Range: 15-82 | 64 | White: 80 Black: 8 Hispanic: 8 Asian: 2 Other: 2 | 19 (13) Range: 2-65 | TNSS: 2.09 (0.44)
Philip, 2002 | 602 | Loratadine 10mg | 36 (13) Range: 15-74 | 65 | White: 84 Black: 6 Hispanic: 4 Other: 6 | 18 (12) | TNSS: 2.06 (0.41)
| 348 | Montelukast 10mg | 37 (13) Range: 15-76 | 67 | White: 83 Black: 6 Hispanic: 4 Other: 8 | 18 (12) | TNSS: 2.09 (0.44)
van Adelsberg, 2003 (Trial1) | 171 | Loratadine 10mg | 35 (13) Range: 15-72 | 58 | White: 82 Black: 5 Hispanic: 4 Other: 8 | 18 (12) | TNSS: 2.15 (0.45)
| 522 | Montelukast 10mg | 36 (14) Range: 15-82 | 62 | White: 82 Black: 7 Hispanic: 3 Other: 8 | 17 (12) | TNSS: 2.10 (0.43)
van Adelsberg, 2003 (Trial 2) | 180 | Loratadine 10mg | 39 (13) | 66 | White: 81 Black: 13 Hispanic: 2 Other: 4 | 21 (13) | TNSS: 2.23 (0.44)
| 448 | Montelukast 10mg | 36 (13) Range: 15-82 | 67 | White: 82 Black: 9 Hispanic: 5 Other: 4 | 19 (12) | TNSS: 2.20 (0.46)

n = Patients randomized to comparator groups of interest, unless otherwise noted; NSS = nasal symptom score; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms). TNSS scores are the mean of individual symptoms with a maximum score of 3.

Appendix Table C25 USPSTF quality assessment: oral selective antihistamine versus leukotriene receptor antagonist

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Baena-Cagnani, 2003 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Lombardo, 2006 | No | Yes | Yes | Yes | Yes | Yes | No | Poor
Lu, 2009 (Trial 1) | Yes | Yes | Yes | Uncertain | Yes | Yes | No | Poor
Lu, 2009 (Trial 2) | Yes | Yes | Yes | Uncertain | Yes | Yes | No | Poor
Meltzer, 2000 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Nayak, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Philip, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
van Adelsberg, 2003 (Trial1) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
van Adelsberg, 2003 (Trial 2) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair

USPSTF = United States Preventive Services Task Force.

Appendix Table C26 Nasal symptom outcomes: mean change from baseline–oral selective antihistamine versus leukotriene receptor antagonist

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS (95% CI) | p
Lu, 2009 (Trial 1) | Loratadine 10mg | 116/115 | 2 | | | | | | | | | -0.53 (-0.63, -0.42) | NR
| Montelukast 10mg | 112/111 | 2 | | | | | | | | | -0.36 (-0.46, -0.25) | NR
Lu, 2009 (Trial 2) | Loratadine 10mg | 164/162 | 2 | | | | | | | | | -0.40 (-0.49, -0.30) | NR
| Montelukast 10mg | 103/103 | 2 | | | | | | | | | -0.39 (-0.50, -0.27) | NR
Meltzer, 2000 | Loratadine 10mg | 92/90 | 2 | -0.33 | NR | -0.42 | NR | -0.49 | NR | -0.45 | NR | -0.34 (-0.44, 0.23) | NR
| Montelukast 10mg | 95/94 | 2 | -0.41 | | -0.49 | | -0.47 | | -0.40 | | -0.36 (-0.47, -0.26) | NR
Nayak, 2002 | Loratadine 10mg | 155^a^ | 2 | -0.20 | NR | -0.25 | NR | -0.33 | NR | -0.30 | NR | -0.48 (-0.57, -0.40) | NR
| Montelukast 10mg | 301^a^ | 2 | -0.22 | | -0.28 | | -0.21 | | -0.23 | | -0.52 (-0.58, -0.46)
Philip, 2002 | Loratadine 10mg | 602^a^ | 2 | -0.24 | NR | -0.24 | NR | -0.36 | NR | -0.26 | NR | -0.50 | NR
| Montelukast 10mg | 348^a^ | 2 | -0.13 | | -0.14 | | -0.18 | | -0.12 | | -0.40 | NR
van Adelsberg, 2003-1 | Loratadine 10mg | 171/170 | 2 | | | | | | | | | -0.47 (-0.55, -0.39) | NR
| Montelukast 10mg | 522/519 | 2 | | | | | | | | | -0.38 (-0.43, -0.33) | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^a^ | 2 | | | | | | | | | -0.45 (-0.52, -0.37) | NR
| Montelukast 10mg | 448^a^ | 2 | | | | | | | | | -0.33 (-0.37, -0.28) | NR
Lombardo, 2006 | Levocetirizine 5mg | 96/96 | 4 | | | | | | | | | -0.43 (-0.47, -0.28) | NR
| Montelukast 10mg | 104/104 | 4 | | | | | | | | | -0.34 (-0.39, -0.18)
van Adelsberg, 2003-2 | Loratadine 10mg | 180^a^ | 4 | | | | | | | | | -0.50 (-0.58, -0.42) | NR
| Montelukast 10mg | 448^a^ | 4 | | | | | | | | | -0.43 (-0.48, -0.38) | NR

CI =Confidence interval; N/n = number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; TNSS = total nasal symptom score.

Entries for each symptom represent the mean change from baseline symptom score using a 0 (no symptom) to 3 (severe symptom) rating scale. Lombardo, 2006 reported change from baseline using mean scores during week 4 rather than during the entire treatment period.TNSS scores are a mean of individual symptoms with a maximum score of 3 unless otherwise noted.

a Only patients randomized reported.

Appendix Table C27 Eye symptom outcomes–oral selective antihistamine versus leukotriene receptor antagonist

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline (95%CI) | p
Meltzer, 2000 ^c^ | Loratadine 10mg | 92/90 | 2 | TOSS (scale 0-3) | 1.41 (0.76) | -0.25 (-0.37, 0.12) | NR
| Montelukast 10mg | 95/94 | 2 | | 1.47 (0.68) | -0.28 (-0.40, 0.15) | NR
van Adelsberg, 2003-1 | Loratadine 10mg | 171/170 | 2 | TOSS (scale 0-3) | 1.48 (0.79) | -0.40 (-0.47, -0.32) | NR
| Montelukast 10mg | 522/519 | 2 | | 1.49 (0.77) | -0.28 (-0.32, -0.23) | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^a^ | 2 | TOSS (scale 0-3) | 1.64 (0.78) | -0.33 (-0.41, -0.26) | NR
| Montelukast 10mg | 448^a^ | 2 | | 1.64 (0.73) | -0.28 (-0.33, -0.23) | NR
Lombardo, 2006 | Levocetirizine 5mg | 96/96 | 4 | TOSS (scale 0-3) | 1.45 (0.68) | -0.38 (-0.45, -0.19) | NR
| Montelukast 10mg | 104/104 | 4 | | 1.36 (0.69) | -0.22 (-0.25, -0.10) | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^a^ | 4 | TOSS (scale 0-3) | | -0.39 (-0.47, -0.31) | NR
| Montelukast 10mg | 448^a^ | 4 | | | -0.37 (-0.42, -0.31) | NR

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; TOSS = total ocular symptom score.

Values are presented as mean (standard deviation) unless otherwise noted. TOSS is the mean of scores for 4 ocular symptoms (itching, tearing, redness, and puffiness) using a 0 (no symptom) to 3 (severe symptom) rating scale.

a Only patients randomized reported.

Appendix Table C28 Asthma outcomes–oral selective antihistamine versus leukotriene receptor antagonist

Author, year | Drug, Dose/Day | N^a^ | Time, weeks | Outcome | Mean Baseline | End of treatment | Mean Change from Baseline | P
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 2 | Triamcinolone acetonide SS | 5.17 | | -1.17 | NS
| Montelukast 10mg | 311 | 2 | | 5.11 | | -1.26 | NS
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 2 | Rescue medication use^b^ | | -13.9 | | 0.134
| Montelukast 10mg | 311 | 2 | | | -16.3 | | 0.134
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 4 | Triamcinolone acetonide SS | | | -1.36 | NS
| Montelukast 10mg | 311 | 4 | | | | -1.52 | NS
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 4 | Rescue medication use^b^ | | -12.1 | | 0.078
| Montelukast 10mg | 311 | 4 | | | -15.9 | | 0.078
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 4 | Cough | 1.64 | | -0.48^c^ | NS
| Montelukast 10mg | 311 | 4 | | 1.61 | | -0.50^c^ | NS
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 4 | Wheeze | 1.70 | | -0.53^c^ | NS
| Montelukast 10mg | 311 | 4 | | 1.71 | | -0.57^c^ | NS
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 4 | Difficulty breathing | 1.82 | | -0.56^c^ | NS
| Montelukast 10mg | 311 | 4 | | 1.80 | | -0.62^c^ | NS
Baena-Cagnani, 2003 | Desloratadine 5mg | 96^d^ | 4 | FEV_1_^d^ | 2.55 | | -0.15 | NS
| Montelukast 10mg | 101^d^ | 4 | | 2.55 | | -0.18 | NS

FEV_1_ = Forced expired volume in 1 second; NS= non-significant; TA = Triamcinolone acetonide; TASS = total asthma symptom score.

a Only patients analyzed reported.

b Change in number of puffs of B-agonist use.

c Values extracted from figures using Engauge Digitizer software.

d In patients with baseline FEV1 <80%.

Appendix Table C29 Quality of life outcomes–oral selective antihistamine versus leukotriene receptor antagonist

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline Mean^a^ | Change from Baseline (95% CI) | P
2 week outcomes
Meltzer, 2000 c | Loratadine 10mg | 92/90 | 2 | RQLQ | 3.00 (1.02) | -0.9 | NR
| Montelukast 10mg | 95/94 | 2 | | 3.33 (0.98) | -0.9 | NR
Nayak, 2002 | Loratadine 10mg | 155^b^ | 2 | RQLQ | 3.14 (0.98) | -1.09 (-1.26, -0.92) | NR
| Montelukast 10mg | 301^b^ | 2 | | 3.10 (1.02) | -1.06 (-1.19, 0.93) | NR
Philip, 2002 | Loratadine 10mg | 602^b^ | 2 | RQLQ | 3.09 (1.03) | -0.99 (-1.08, -0.90) | NR
| Montelukast 10mg | 348^b^ | 2 | | 3.12 (0.99) | -0.89 (-1.01, -0.77) | NR
van Adelsberg, 2003-1 | Loratadine 10mg | 171/170 | 2 | RQLQ | 3.24 (0.97) | -0.98 (-1.15, -0.81) | NR
| Montelukast 10mg | 522/519 | 2 | | 3.22 (1.06) | -0.90 (-1.00, -0.81) | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^b^ | 2 | RQLQ | 3.46 (1.08) | -0.85 (-1.00, -0.70) | NR
| Montelukast 10mg | 448^b^ | 2 | | 3.41 (1.00) | -0.85 (-0.94, -0.75) | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^b^ | 2 | PGA^c^ | | 2.30^d^ (2.08, 2.52) | NR
| Montelukast 10mg | 448^b^ | 2 | | | 2.43^d^ (2.29, 2.57) | NR
4 week outcomes
Lombardo, 2006 | Levocetirizine 5mg | 96/96 | 4 | RQLQ | 3.14 (0.95) | 0.78 | NR
| Montelukast 10mg | 104/104 | 4 | | 3.09 (0.88) | 0.65 | NR
van Adelsberg, 2003-2 | Loratadine 10mg | 180^b^ | 4 | RQLQ | | -1.08 (-1.25, -0.91) | NR
| Montelukast 10mg | 448^b^ | 4 | | | -1.12 (-1.23, -1.01) | NR

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; PGA = patient global assessment; RQLQ = Rhinitis Quality of Life Questionnaire.

a Values are presented as mean (standard deviation) unless otherwise noted.

b Only patients randomized are reported.

c PGA of allergic rhinitis was scored on a 0 (best) to 6 (worst) scale.

d Values are absolute scores at week 2.

## Intranasal Corticosteroid Versus Nasal Antihistamine

Appendix Table C30 Trial description: intranasal corticosteroid versus nasal antihistamine

Author, Year | Location/Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Carr, 2012 (Trial 1) | N.America Multiple | March 2008 2 weeks | Industry Yes | 415 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Carr, 2012 (Trial 2) | N.America Multiple | August 2009 2 weeks | Industry Yes | 383 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Carr, 2012 (Trial 3) | N.America Multiple | April 2009 2 weeks | Industry Yes | 895 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Ghimire, 2007 | Asia Single | 4 weeks | NR NR | 50 | | SAR meds/NR Other meds Pregnancy Deformities | No | | | | Open Label trial
Hampel, 2010 | N.America Multiple | January 2007 2 weeks | Industry Yes | 305 | Minimum SAR severity and duration | SAR meds/- Other meds Infection Deformities | No | • | • | | • | •
Kaliner, 2009 | N.America Multiple | 2 weeks | Industry Yes | 130 | Minimum SAR severity and duration | SAR meds/+ Other meds Chronic asthma Pregnancy Infection Deformities | No | • | | | Inadequate | •
Newson-Smith, 1997 | Europe Multiple | April 1991 2 weeks | NR Yes | 166 | Minimum SAR severity and duration | SAR meds/+ Immunotherapy Pregnancy Deformities | No | | • | | Inadequate | •
Pelucchi, 1995 | Europe | April 1993 6 weeks | NR NR | 30 | Minimum SAR duration | Chronic asthma Immunotherapy Deformities | Yes | • | | • | • | •
Ratner, 2008 | N.America Multiple | December 2005 2 weeks | Industry Yes | 99 | Minimum SAR severity and duration | SAR meds/+ Other meds | No | • | • | • | • | •

N = Patients randomized to comparator groups of interest; NR = not reported.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C31 Patient characteristics: intranasal corticosteroid versus nasal antihistamine

Author, Year | n | Drug, Dose/Day | Mean Age, years | Sex, % Female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Carr, 2012 (Trial 1) | 207 | Fluticasone propionate 200mcg | 38.6 (14.1) | 61.4 | White: 77.8 | 21.3 (13.5) | C: 5.0 (0.9)^b^ S: 4.1 (1.2)^b^ R: 4.6 (1.0)^b^ I: 4.5 (1.1)^b^ TNSS: 18.2 (3.2)^b^
| 208 | Azelastine 548mcg | 36.2 (14.6) | 62.5 | White: 77.9 | 21.6 (13.6) | C: 5.1 (0.8)^b^ S: 4.0 (1.3)^b^ R: 4.5 (1.2)^b^ I: 4.5 (1.2)^b^ TNSS: 18.2 (3.5)^b^
Carr, 2012 (Trial 2) | 189 | Fluticasone propionate 200mcg | 37.0 (13.6) | 64 | White: 74.1 | 21.1 (13.7) | C: 5.0 (0.8)^b^ S: 4.2 (1.3)^b^ R: 4.6 (1.0)^b^ I: 4.8 (0.9)^b^ TNSS: 18.6 (2.9)^b^
| 194 | Azelastine 548mcg | 38.2 (13.5) | 66 | White: 78.9 | 19.7 (13.1) | C: 5.1 (0.8)^b^ S: 4.2 (1.3)^b^ R: 4.5 (1.1)^b^ I: 4.7 (1.1)^b^ TNSS: 18.5 (3.1)^b^
Carr, 2012 (Trial 3) | 450 | Fluticasone propionate 200mcg | 34.2 (14.5) | 62.2 | White: 79.1 | 19.6 (12.5) | C: 5.3 (0.7)^b^ S: 4.5 (1.2)^b^ R: 4.8 (0.9)^b^ I: 4.9 (0.9)^b^ TNSS: 19.4 (2.4)^b^
| 445 | Azelastine 548mcg | 36.4 (14.8) | 60.9 | White: 80.2 | 19.5 (12.9) | C: 5.3 (0.7)^b^ S: 4.5 (1.1)^b^ R: 4.8 (0.9)^b^ I: 4.9 (0.9)^b^ TNSS: 19.5 (2.5)^b^
Ghimire, 2007 | 25 | Beclomethasone dipropionate 400mcg | | | | | C: 2.2 S: 2.7 R: 2.6
| 25 | Azelastine 1120mcg | 27^c,d^ Range: 12-69 IQR: 20-30 | 48 | Unspecified | | C: 1.8 S: 2.6 R: 2.7
Hampel, 2010 | 153 | Fluticasone propionate 200mcg | 38.1 Range: 12-74 | 66.2 | White: 86.1 Black: 10.6 Asian: 2.0 Other: 1.3 | 18.4 Range: 3-57 | TNSS: 18.3^b^
| 152 | Azelastine 548mcg | 39.5 Range: 12-74 | 63.8 | White: 88.8 Black: 9.9 Asian: 0.0 Other: 1.3 | 19.0 Range: 2-61 | TNSS: 18.1^b^
Kaliner, 2009 | 65 | Fluticasone propionate 200mcg | 32.48 (10.83) Range: 13-60 | 47.6 | White: 56.3 Black: 18.8 Hispanic: 12.5 Asian: 10.9 Other: 1.6 | | TNSS: 6.49 (1.66)
| 65 | Olopatadine 4 puffs/nostril | 38.14 (15.25) Range: 12-73 | 53.1 | White: 56.3 Black: 23.4 Hispanic: 12.5 Asian: 6.3 Other: 1.6 | | TNSS: 6.72 (1.88)
Newson-Smith, 1997 | 83 | Beclomethasone dipropionate 400mcg
| 83 | Azelastine 1120mcg | 35^c,d^ | | Unspecified
Pelucchi, 1995 | 15^e^ | Beclomethasone dipropionate 200mcg | 26 (8) | 38.5 | Unspecified
| 15^e^ | Azelastine 560mcg | 26 (9) | 30 | Unspecified
Ratner, 2008 | 50 | Fluticasone propionate 200mcg | 37.4 Range: 12-72 | 70 | White: 64.0 Black: 4.0 Hispanic: 26.0 Asian: 6.0 Other: 0 | 15.7 Range: 3-51 | C: 5.5 (0.4)^b^ S: 4.3 (1.3)^b^ R: 5.0 (1.0)^b^ I: 4.8 (1.3)^b^ TNSS: 19.6 (2.7)^b^
| 49 | Azelastine 4 puffs/nostril | 38.4 Range: 12-73 | 55.1 | White: 73.5 Black: 10.2 Hispanic: 14.3 Asian: 0 Other: 2.0 | 19.2 Range: 3-50 | C: 5.5 (0.5)^b^ S: 4.5 (1.1)^b^ R: 4.9 (0.8)^b^ I: 4.8 (0.8)^b^ TNSS: 19.7 (2.1)^b^

C = congestion; I = itching; n = patients randomized to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) except as noted. TNSS ranges from 0 to 12.

b Individual symptoms rated on a scale from 0 (no symptoms) to 6 (severe symptoms). TNSS is the sum of AM and PM scores and ranges from 0 to 24.

c Values are medians.

d Overall demographic info provided only.

e Only patients randomized are reported.

Appendix Table C32 USPSTF quality assessment: intranasal corticosteroid versus nasal antihistamine

Author | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Carr, 2012 (Trial 1) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Carr, 2012 (Trial 2) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Carr, 2012 (Trial 3) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Ghimire, 2007 | No | Uncertain | Uncertain | No | Yes | No | No | Poor
Hampel, 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kaliner, 2009 | Yes | Uncertain | Yes | No | Yes | Yes | Yes | Poor
Newson-Smith, 1997 | Yes | Yes | Uncertain | No | Yes | Yes | No | Poor
Pelucchi, 1995 | No | Uncertain | Yes | Yes | Yes | Yes | No | Poor
Ratner, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

USPSTF = United States Preventive Services Task Force.

Appendix Table C33 Nasal symptom outcomes: change from baseline–intranasal corticosteroid versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS | p
Carr, 2012 (Trial 1) | Fluticasone propionate 200mcg | 207/207 | 2 | -1.2 (1.3) | NR | -1.3 (1.4) | NR | -1.5 (1.4) | NR | -1.3 (1.3) | NR | -5.0 (4.7)^a^ | NR
| Azelastine 548mcg | 208/208 | 2 | -0.9 (1.3) | NR | -1.1 (1.4) | NR | -1.3 (1.3) | NR | -0.9 (1.3) | NR | -4.1 (4.6)^a^ | NR
Carr, 2012 (Trial 2) | Fluticasone propionate 200mcg | 189/189 | 2 | -1.1 (1.5) | NR | -1.3 (1.5) | NR | -1.4 (1.5) | NR | -1.2 (1.4) | NR | -5.0 (5.2)^a^ | NR
| Azelastine 548mcg | 194/194 | 2 | -1.0 (1.3) | NR | -1.0 (1.3) | NR | -1.3 (1.5) | NR | -1.1 (1.3) | NR | -4.4 (4.6)^a^ | NR
Carr, 2012 (Trial 3) | Fluticasone propionate 200mcg | 450/450 | 2 | -1.1 (1.2) | NR | -1.3 (1.4) | NR | -1.5 (1.5) | NR | -1.2 (1.3) | NR | -5.1 (4.7)^a^ | NR
| Azelastine 548mcg | 445/445 | 2 | -1.0 (1.2) | NR | -1.2 (1.4) | NR | -1.4 (1.5) | NR | -1.1 (1.4) | NR | -4.5 (4.8)^a^ | NR
Ghimire, 2007 | Beclomethasone dipropionate 400mcg | 25^b,c^ | 2 | -1.8^d^ | NR | -2.2^d^ | NR | -2.3^d^ | NR
| Azelastine 1120mcg | 25^b,c^ | 2 | -1^d^ | NR | -2.2^d^ | NR | -2.2^d^ | NR
Hampel, 2010 | Fluticasone propionate 200mcg | 153/151 | 2 | -0.86 | NR | -1.15 | NR | -0.98 | NR | -0.91 | NR | -3.84 (4.76)^a^ | NR
| Azelastine 548mcg | 152/152 | 2 | -0.75 | NR | -0.87 | NR | -0.86 | NR | -0.82 | NR | -3.25 (4.16)^a^ | NR
Kaliner, 2009 | Fluticasone propionate 200mcg | 65/65 | 2 | -29.3 e | NS | -40.3 e | NS | -41 e | NS | -42.8 e | NS | 3.1^d^ | 0.68
| Olopatadine 4 puffs/nostril | 65/65 | 2 | -22.4^e^ | NS | -38.7^e^ | NS | -53.9^e^ | NS | -29.4^e^ | NS | 3.2^d^ | 0.68
Newson-Smith, 1997 | Beclomethasone dipropionate 400mcg | 83^b,c^ | 2 | -0.8 | NS | -1 | NS | -1 | NS | -0.9 | NS
| Azelastine 1120mcg | 83^b,c^ | 2 | -0.3 | NS | -0.6 | NS | -0.6 | NS | -0.5 | NS
Pelucchi, 1995 | Beclomethasone dipropionate 200mcg | 15/13 | 2 | | | | | | | | | | NS
| Azelastine 560mcg | 15/10 | 2 | | | | | | | | | | NS
Ratner, 2008 | Fluticasone propionate 200mcg | 50/49 | 2 | -1.1 (1.2) | NR | -1.3 (1.2) | NR | -1.5 (1.5) | NR | -1.3 (1.5) | NR | -5.2 (4.6)^a^ | NR
| Azelastine 4 puffs/nostril | 49/49 | 2 | -1.1 (1.5) | NR | -1.1 (1.4) | NR | -1.5 (1.0) | NR | -1.1 (1.4) | NR | -4.8 (4.3)^a^ | NR
Ghimire, 2007 | Beclomethasone dipropionate 400mcg | 25^b,c^ | 3 | -0.3^f^ | NR | -0.3^f^ | NR | -0.2^f^ | NR
| Azelastine 1120mcg | 25^b,c^ | 3 | -0.8^f^ | NR | -0.3^f^ | NR | -0.2^f^ | NR
Pelucchi, 1995 | Beclomethasone dipropionate 200mcg | 15/13 | 3 | | | | | | | | | -3.4^g^ | NS
| Azelastine 560mcg | 15/10 | 3 | | | | | | | | | -4.5^g^ | NS
Ghimire, 2007 | Beclomethasone dipropionate 400mcg | 25^b,c^ | 4 | -0.1^h^ | NR | -0.1^h^ | NR | -0.1^h^ | NS
| Azelastine 1120mcg | 25^b,c^ | 4 | -0.6^h^ | NR | -0.1^h^ | NR | -0.1^h^ | NS
Pelucchi, 1995 | Beclomethasone dipropionate 200mcg | 15/13 | 4 | | | | | | | | | -2.7^i^ | NS
| Azelastine 560mcg | 15/10 | 4 | | | | | | | | | -3.7^i^ | NS
Pelucchi, 1995 | Beclomethasone dipropionate 200mcg | 15/13 | 5 | | | | | | | | | -2.1^j^ | NS
| Azelastine 560mcg | 15/10 | 5 | | | | | | | | | -3.5^j^ | NS

N/n = Number of patients randomized/number of patients analyzed; NR = not reported; NS = non-significant; TNSS = total nasal symptom score.

Except as noted, entries for each symptom represent the mean change from baseline symptom score using a 0 (no symptom) to 3 (severe symptom) rating scale. TNSS ranges from 0 to 12.

Values in parentheses are standard deviations.

a TNSS is a sum of AM and PM scores ranging from 0 to 24.

b Overall demographic info provided only.

c Only patients randomized are reported.

d Values calculated by report author.

e Percent change from baseline.

f Endpoint for third week.

g Average for third week.

h Endpoint for fourth week.

i Average for fourth week.

j Average for fifth week.

Appendix Table C34 Eye symptom outcomes–intranasal corticosteroid versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline Mean (SD) | Change from Baseline | p
Carr, 2012 (Trial 1) (scale 0-18) | Fluticasone propionate 200mcg | 207/207 | 2 | TOSS (scale 0-18) | 11.4 (4.4) | -2.6 (3.5) | NR
| Azelastine 548mcg | 208/208 | 2 | TOSS (scale 0-18) | 11.5 (4.5) | -2.8 (3.8)
Carr, 2012 (Trial 2) (scale 0-18) | Fluticasone propionate 200mcg | 189/189 | 2 | TOSS (scale 0-18) | 12.0 (3.8) | -2.7 (3.6) | NR
| Azelastine 548mcg | 194/194 | 2 | TOSS (scale 0-18) | 11.8 (3.9) | -3.0 (3.3)
Carr, 2012 (Trial 3) (scale 0-18) | Fluticasone propionate 200mcg | 450/450 | 2 | TOSS (scale 0-18) | 12.3 (3.6) | -2.8 (3.5) | NR
| Azelastine 548mcg | 445/445 | 2 | TOSS (scale 0-18) | 12.4 (4.0) | -3.0 (3.8)
Hampel, 2010 (scale 0-18) | Fluticasone propionate 200mcg | 153/151 | 2 | TOSS (scale 0-18) | | -2.17 | NR
| Azelastine 548mcg | 152/152 | 2 | TOSS (scale 0-18) | | -2.62 | NR
Kaliner, 2009 (scale 0-9) | Fluticasone propionate 200mcg | 65/65 | 2 | TOSS (scale 0-9) | 4.18 (1.84) | -1.7^a^ | 0.6064
| Olopatadine 4 puffs/nostril | 65/65 | 2 | TOSS (scale 0-9) | 4.25 (2.05) | -1.64^a^ | 0.6064

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; TOSS = total ocular symptom score.

Values in parentheses are standard deviations. TOSS is the sum of scores for 3 ocular symptoms (itching, tearing, and redness).

a Values calculated by report author.

Appendix Table C35 Quality of life outcomes–intranasal corticosteroid versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline Mean (SD) | Change from Baseline | p
Hampel, 2010 | Fluticasone propionate 200mcg | 153/151 | 2 | RQLQ | | -1.43 | NR
| Azelastine 548mcg | 152/152 | 2 | RQLQ | | -1.17 | NR
Ratner, 2008 | Fluticasone propionate 200mcg | 50/49 | 2 | RQLQ | 3.95 (1.14) | -1.47 | NR
| Azelastine 4 puffs/nostril | 49/49 | 2 | RQLQ | 3.66 (1.13) | -1.21 | NR

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NR = not reported; RQLQ = Rhinitis Quality of Life Questionnaire.

## Intranasal Corticosteroid Versus Nasal Cromolyn

Appendix Table C36 Trial description: intranasal corticosteroid versus nasal cromolyn

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Bjerrum, 1985 | Europe Single | 3 weeks | Industry NR | 43 | Minimum SAR duration | Other meds Chronic asthma Pregnancy Infection Deformities | Yes | • | • | | • | •
Bousquet, 1993 | Europe Multiple | 6 weeks | NR Yes | 218 | Minimum SAR duration | SAR meds/- Pregnancy Infection | Yes | • | | • | • | •
Lange, 2005 | Europe Single | May 2003 4 weeks | Industry NR | 83 | Minimum SAR severity and duration | SAR meds/+ Other meds Chronic asthma Infection Deformities | Yes | • | • | • | Open label trial | Open label trial
Welsh, 1987 | N.America | July 1984 8 weeks | Industry NR | 90 | Minimum SAR duration | Pregnancy Deformities | Yes | • | • | • | | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C37 Patient characteristics: intranasal corticosteroid versus nasal cromolyn

Author, Year | Drug Dose/Day | N | Mean Age, years | Sex, % female | Race, % | Disease Duration, Years | Mean Baseline TNSS^a^
Bjerrum, 1985 | Budesonide 400 mcg^b^ | 22 | 29 Range: 15-55 | 48.9^C^ | Unspecified | | 1.99
| Cromolyn 26 mg^d^ | 21 | | | | | 3.29
Bousquet, 1993 | Fluticasone propionate, 200 mcg^g^ | 110 | 32 (12) | | Unspecified
| Cromolyn 20.8 mg e | 108 | 32 (12) | | Unspecified
Lange, 2005 | Mometasone furoate 200 mcg^e^ | 41 | 35.5 (9.6) | 56.1 | Unspecified
| Cromolyn 22.4 mg^f^ | 42 | 33.5 (8.2) | 66.7 | Unspecified
Welsh, 1987 | Beclomethasone dipropionate 336 mcg^b^ | 30 | 27 Range: 13-50 | 30.0 | Unspecified
| Flunisolide 200 mcg^b^ | 30 | 27 Range: 14-44 | 26.7 | Unspecified
| Cromolyn 41.6 mg e | 30 | 30 Range: 12-48 | 33.3 | Unspecified

N = Patients randomized to comparator groups of interest; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms). TNSS ranges from 0 to 12.

b Twice daily.

C Overall demographic info provided only.

d Five times daily.

e Once daily.

f Four times daily.

g Every morning.

Appendix Table C38 USPSTF quality assessment: intranasal corticosteroid versus nasal cromolyn

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Bjerrum, 1985 | No | Yes | Yes | Yes | Yes | Yes | Yes | Poor
Bousquet, 1993 | No | No | No | Yes | No | Yes | No | Poor
Lange, 2005 | Yes | Yes | Yes | No | Yes | Yes | Yes | Poor
Welsh, 1987 | Yes | No | No | No | No | Yes | Yes | Poor

USPSTF = United States Preventive Services Task Force.

Appendix Table C39 Nasal symptom outcomes: change from baseline–intranasal corticosteroid versus nasal cromolyn

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS | p
Bjerrum, 1985 | Budesonide 400 mcg^a^ | 22/21 | 2 | -0.22^a^ | <0.05 | -0.35^a^ | <0.01 | -0.10^a^ | <0.01 | -0.06^a^ | <0.01 | -0.73^a^ | <0.01
| Cromolyn 26 mg^c^ | 21/21 | | 0.13^a^ | | 0.24^a^ | | 0.28^a^ | | 0.15^a^ | | 0.80^a^
Bjerrum, 1985 | Budesonide 400 mcg^a^ | 22/21 | 3 | -0.15^a^ | NS | -0.24^a^ | <0.05 | -0.01^a^ | <0.02 | -0.01^a^ | <0.02 | -0.39^a^ | <0.01
| Cromolyn 26 mg^c^ | 21/21 | | 0.13^a^ | | 0.25^a^ | | 0.26^a^ | | -0.16^a^ | | 0.80^a^
Bousquet, 1993 | Fluticasone propionate 200 mcg^f^ | 110/73 | 6 | | 0.01 | | 0.01 | | 0.02 | | 0.03
| Cromolyn 20.8 mg ^e^ | 108/87
Lange, 2005 | Mometasone furoate 200 mcg^d^ | 41/40 | 4 | | 0.05^b^ | | <0.01^b^ | | <0.01^b^ | | <0.01^b^ | | <0.01^b^
| Cromolyn, 22.4 mg^e^ | 42/42

N/n = Number of patients randomized/number of patients analyzed; NS, not significant; TNSS = total nasal symptom score.

Entries for each symptom represent the mean change from baseline symptom score using a 0 (no symptom) to 3 (severe symptom) rating scale. TNSS ranges from 0 to 12.

a Calculated by report author using pre/post data.

b Comparisons are between final outcome scores, not change in scores.

Appendix Table C40 Quality of life outcomes: intranasal corticosteroid versus nasal cromolyn

Author, year | Drug, Dose/Day | N/n | Time, weeks | PGA | Result | p
Lange, 2005 | Mometasone furoate 200 mcg | 41/40 | 4 | % reporting very good/good treatment efficacy^a^ | 92.3 | <0.001^b^
| Cromolyn 22.4 mg | 42/42 | | | 62.4
Welsh, 1987 | Beclomethasone dipropionate 336 mcg | 30/28 | 8 | % reporting substantial symptom control^c^ | 75.0 | <0.001^b^
| Flunisolide 200 mcg | 30/30 | | | 80.0
| Cromolyn 41.6 mg | 30/28 | | | 55.2

N/n = Number of patients randomized/number of patients analyzed; PGA = patient global assessment.

a 4-point scale: very good, good, slight, insufficient.

b Statistical testing is over all PGA categories.

c 3-point scale: substantial, some, none.

## Intranasal Corticosteroid Versus Oral Leukotriene Receptor Antagonist

Appendix Table C41 Trial description: intranasal corticosteroid versus leukotriene receptor antagonist

Author, Year | Location/Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Lu, 2009 (Trial 1) | N.America Multiple | April 1998 2 weeks | Industry/Industry | 285 | Minimum SAR severity and duration | | No | • | • | | • | •
Martin, 2006 | N.America Multiple | December 2001 2 weeks | Industry/Industry | 736 | Minimum SAR severity and duration | SAR meds/NR Other meds Pregnancy Deformities | No | • | • | | • | •
Nathan, 2005 | N.America Multiple | 4 weeks | Industry/Industry | 573 | Minimum SAR severity and duration | SAR meds/+ Pregnancy Infection Deformities | Yes | • | • | | • | •
Pullerits, 2002 | Europe | 03/1999 8 weeks | Industry/ | 29 | Minimum SAR duration | Other meds Pregnancy Infection | Yes | • | • | • | • | •
Ratner, 2003 | N.America Multiple | December 2001 2.1 weeks | Industry/Industry | 705 | Minimum SAR severity and duration | SAR meds Other meds Pregnancy Deformities | No | • | • | | • | •

N = patients randomized to comparator groups of interest; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C42 Patient characteristics: intranasal corticosteroid versus leukotriene receptor antagonist

Author, Year | n | Drug Dose/Day | Mean Age, years | Sex, % Female | Race, % | Disease Duration, years | Mean Baseline NSS
Lu, 2009 (Trial 1) | 173 | Beclomethasone dipropionate 400 mcg | 34.1(13.3) | 61.3 | White: 79.2 Black: 8.1 Hispanic: 8.1 Other: 4.6 | 17.9 ( 12.2) | TNSS: 2.03^a^
| 112 | Montelukast 10 mg | 35.6 (13.1) | 62.5 | White: 79.5 Black: 5.4 Hispanic: 8.9 Other: 6.3 | 18.8 (10.7) | TNSS: 2.06^a^
Martin, 2006 | 367 | Fluticasone propionate 200 mcg | 39.1 (14.0) | 64 | Unspecified | 15.1 (11.0) | C: 78.0 (0.8)^b^ R: 74.9 (0.9)^b^ S: 71.9 (1.0)^b^ I: 73.3 (0.9)^b^ TNSS: 298.2 (2.8)^c^
| 369 | Montelukast 10 mg | 40.3 (13.9) | 62 | Unspecified | 15.2 (11.8) | C: 78.7 (0.8)^b^ R: 76.3 (0.9)^b^ S: 72.2 (1.0)^b^ I: 74.3 (0.9)^b^ TNSS: 301.5 (2.8)^c^
Nathan, 2005 | 291 | Fluticasone propionate 200 mcg | 35.8 (12.6) | 67 | White: 76 Black: 11 Hispanic: 11 Asian: 1 Other: 1 | | C: 71.5 (1.3)^b^ R: 65.7 (1.5)^b^ S: 59.8 (1.6)^b^ I: 63.7 (1.5)^b^ TNSS: 260.7 (4.6)^c^
| 282 | Montelukast 10 mg | 34.4 (13.3) | 66 | White: 77 Black: 11 Hispanic: 8 Asian: 2 Other: 1 | | C: 73.0 (1.3)^b^ R: 66.6 (1.5)^b^ S: 62.7 (1.7)^b^ I: 66.8 (1.6)^b^ TNSS: 269.1 (4.7)^c^
Pullerits, 2002 | 13 | Fluticasone propionate 200 mcg | 28.4 (6.4) | 46.2 | Unspecified | ≤5 years: 8% >5 years: 92% | TNSS: 1.5 (1.4)^d^
| 16 | Montelukast 10 mg | 28.3 (8.0) | 37.5 | Unspecified | ≤5 years: 25% >5 years: 75% | TNSS: 1.9 (2.1)^d^
Ratner, 2003 | 353 | Fluticasone propionate 200 mcg | 38.3 (13.3) | 61 | Unspecified | Mean: 15.7 (11.8) | C: 77.5 (0.8)^b^ R: 75.2 (0.9)^b^ S: 71.0 (1.0)^b^ I: 72.6 (0.9)^b^ TNSS: 296.2 (2.7)^c^
| 352 | Montelukast 10 mg | 38.1 (13.3) | 63 | Unspecified | Mean: 15.4 (12.1) | C: 78.3 (0.8)^b^ R: 75.9 (0.9)^b^ S: 72.0 (1.0)^b^ I: 72.7 (0.9)^b^ TNSS: 298.9 (2.7)^c^

C = Congestion; I = itching; n = patients randomized to comparator groups of interest; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a TNSS scale 0 (no symptoms) to 3 (severe symptoms) using symptom categories for each symptom, which were then averaged by the investigators.

b Individual symptoms scored 0 (no symptoms) to 100 (severe symptoms) using a VAS.

c TNSS scored 0-400, sum of each individual 0 to 100 VAS score.

d TNSS scored 0 to 16, a summation of each individual symptom scored 0 (no symptoms) to 4 (severe symptoms).

Appendix Table C43 USPSTF quality assessment: intranasal corticosteroid versus leukotriene receptor antagonist

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Lu, 2009 | Yes | Uncertain | Yes | Uncertain | Yes | Yes | No | Poor
Martin, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Nathan, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Pullerits, 2002 | Yes | Yes | Uncertain | Yes | Yes | Yes | No | Poor
Ratner, 2003 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Appendix Table C44 Nasal symptom outcomes: change from baseline–intranasal corticosteroid versus leukotriene receptor antagonist

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Rhinorrhea | p | Sneezing | p | Itching | p | TNSS | p
Lu, 2009 (Trial 1) | Beclomethasone dipropionate 400 mcg | 173/172 | 2 | | | | | | | | | -0.7 (-0.78, -0.61) | ≤0.01
| Montelukast 10 mg | 112/111 | 2 | | | | | | | | | -0.36 (-0.46, -0.25)
Martin, 2006 | Fluticasone propionate 200 mcg | 367/364 | 2 | -31.1 (1.2) | <0.01 | -32.9 (1.2) | <0.01 | -33.5 (1.2) | <0. 01 | -32.8 (1.2) | <0.001 | -130.2 (4.7) | <0.01
| Montelukast 10 mg | 369/366 | 2 | -23.1 (1.2) | | -23.5 (1.2) | | -24.9 (1.2) | | -25.0 (1.2) | | -96.6 (4.7)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/291 | 2 | -24.0 (1.6) | <0.01 | -26.5 (1.6) | <0.01 | -25.4 (1.6) | <0.01 | -24.0 (1.6) | <0.001 | -99.1 (5.8) | <0.01
| Montelukast 10 mg | 282/282 | 2 | -16.7 (1.6) | | -18.7 (1.7) | | -19.1 (1.7) | | -18.7 (1.6) | | -73.0 (6.0)
Pullerits, 2002 | Fluticasone propionate 200 mcg | 13^a^ | 2 | | | | | | | | | -0.1 c | NS
| Montelukast 10 mg | 16^a^ | 2 | | | | | | | | | 0.7 c
Ratner, 2003 | Fluticasone propionate 200 mcg | 353/353 | 2 | -31.4 (1.2) | <0.01 | -32.6 (1.2) | <0.01 | -33.7 (1.2) | <0.01 | -32.7 (1.2) | <0.001 | -130.3 (4.7) | <0. 01
| Montelukast 10 mg | 352/352 | 2 | -22.7 (1.2) | | -24.3 (1.2) | | -23.7 (1.2) | | -23.2 (1.2) | | -94.0 (4.7)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/291 | 4 | -29.0 (1.7) | <0.01 | -30.7 (1.7) | <0.01 | -29.3 (1.7) | <0.01 | -28.8 (1.7) | <0.001 | -117.0 (6.2) | <0.01
| Montelukast 10 mg | 282/282 | 4 | -20.7 (1.7) | | -22.7 (1.7) | | -23.1 (1.7) | | -22.8 (1.7) | | -89.1 (6.4)
Pullerits, 2002 | Fluticasone propionate 200 mcg | 13^a^ | 5 b | | | | | | | | | 1.1 d | NS
| Montelukast 10 mg | 16^a^ | 5^b^ | | | | | | | | | 2.5 d
Pullerits, 2002 | Fluticasone propionate 200 mcg | 13^a^ | 8 c | | | | | | | | | -0.4 d | <0.05
| Montelukast 10 mg | 16^a^ | 8^c^ | | | | | | | | | 0.3 d

N/n = Number of patients randomized/number of patients analyzed; NS = non-significant; TNSS = total nasal symptom score.

Values are mean (standard error) change from baseline. Entries for each outcome represent the mean change from baseline symptom score. Nathan, 2005, Nathan, 2005, and Ratner, 2003 used a 0 (no symptoms) to 100 (most severe symptoms) VAS to rate each symptom, then summed the symptom scores for TNSS (maximum, 400). Pullerits, 2002 used a 0 (no symptoms) to 4 (severe symptoms) categorical scale for each symptom, then summed the scores for TNSS (maximum, 16). Lu, 2009 used a 0 (no symptoms) to 3 (severe symptoms) to rate each symptom, then averaged the symptom scores for TNSS (maximum, 3).

a Only patients randomized are reported.

b Average for interval from 3-5 weeks.

c Average for interval from 6-8 weeks.

d Calculated by report author from pre/post data reported.

Appendix Table C45 Quality of life outcomes: intranasal corticosteroid versus leukotriene receptor antagonist

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | End of treatment | p
Martin, 2006 | Fluticasone propionate 200 mcg | 367/364 | 2 | % patients reporting significant or better improvement^a^ | | 42 | <0.001
Martin, 2006 | Montelukast 10 mg | 369/366 | | | | 24
Ratner, 2003 | Fluticasone propionate 200 mcg | 353/353 | 2 | % patients reporting significant improvement^a^ | | 43 | <0.001
Ratner, 2003 | Montelukast 10 mg | 352/352 | | | | 25
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/291 | 4 | % reporting satisfied or better with treatment^a^ | | 69 | <0.001
Nathan, 2005 | Montelukast 10 mg | 282/282 | | | | 55

N/n = Number of patients randomized/number of patients analyzed.

a 7-point Likert Scale.

Appendix Table C46 Asthma outcomes–intranasal corticosteroid versus leukotriene receptor antagonist

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean (SE) | End of treatment | Mean Change from Baseline | p
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/250 | 4 | Morning Peak Expiratory Flow, L/min | 361.3 (7.4) | | + 34.0 (4.3) | NS
| Montelukast 10 mg | 282/247 | | | 367.2 (7.4) | | + 31.6 (4.3)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/250 | 4 | Evening Peak Expiratory Flow, L/min | 375.3 (7.7) | | + 24.9 (4.0) | NS
| Montelukast 10 mg | 282/247 | | | 380.8 (7.7) | | + 23.1 (4.0)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/250 | 4 | Symptom Free Days, % | 5.3 (1.0) | 20.6 (3.3) | | NS
| Montelukast 10 mg | 282/247 | | | 6.8 (1.0) | 23.4 (3.2)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/250 | 4 | Days Free of Albuterol Rx, % | 17.4 (2.2) | 34.8 (3.5) | | NS
| Montelukast 10 mg | 282/247 | | | 18.3 (2.3) | 36.4 (3.5)
Nathan, 2005 | Fluticasone propionate 200 mcg | 291/250 | 4 | % of patients experiencing asthma exacerbations^a^ | | <1 | | NR
| Montelukast 10 mg | 282/247 | | | | 1

N/n = Number of patients randomized/number of patients analyzed; NR = not reported; NS = non-significant; SE = standard error.

a Defined by any asthma-related event that required treatment with asthma medications beyond study medications.

## Combination Oral Selective Antihistamine Plus Intranasal Corticosteroid Versus Oral Selective Antihistamine

Appendix Table C47 Trial description: combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria | Rescue Rx | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Anolik, 2008 | N.America Multiple | March 1995 2.1 weeks | NR Industry | 350 | Minimum SAR severity and duration | Chronic asthma Immunotherapy Infection Deformities | No | • | • | • | • | •
Ratner, 1998 | N.America Multiple | 2 weeks | Industry Industry | 300 | Minimum SAR severity and duration | SAR meds/+ Pregnancy Infection Deformities | No | • | • | | • | •
Wilson, 2000 | Europe Single | June 1998 4 weeks | Academia NR | 27 | Minimum SAR severity | Infection | No | • | • | • | •

N = Patients randomized to comparator groups of interest; NR = not reported.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C48 Patient characteristics: combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N | Mean Age, years | Sex, % female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169 | 26 Range: 11-62 | 50.3 | Unspecified | Mean: 14 Range: 2-51 | C: 2.3 R: 2.1 S: 1.8 I: 1.8 TNSS: 7.9 (2.0)
| Loratadine 10 mg | 181 | 25 Range: 12-65 | 50.3 | Unspecified | Mean: 14 Range: 2-60 | C: 2.3 R: 2.1 S: 1.7 I: 1.9 TNSS: 7.9 (2.2)
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150 | 42.2 Range: 15-78 | 51 | White: 80 Hispanic: 17 Other: 3 | | TNSS: 290
| Loratadine 10 mg | 150 | 40.1 Range: 15-70 | 54 | White: 73 Hispanic: 19 Other: 8 | | TNSS: 300
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14 | 31 (2.7) | 64.3 | Unspecified | | TNSS: 4.8 (0.7)
| Cetirizine 10 mg | 13 | 30 (2.5) | 76.9 | Unspecified | | TNSS: 5.3 (0.8)

C = Congestion; I = itching; n= patients randomized or assigned to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) for each individual symptom. Morning and evening scores were summed (maximum individual symptom = 6, maximum TNSS = 24).

Appendix Table C49 USPSTF quality assessment: combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Anolik, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Ratner, 1998 | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Fair
Wilson, 2000 | Yes | Yes | Uncertain | Yes | Yes | Yes | Yes | Fair

USPSTF = United States Preventive Services Task Force.

Appendix Table C50 Nasal symptom outcomes: change from baseline–combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion^a^ | p versus Combo | Rhinorrhea^a^ | p versus Combo | Sneezing^a^ | p versus Combo | Itching^a^ | p versus Combo | TNSS^a^ | p versus Combo
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169/166 | 2^b^ | -0.7 | | -0.7 | | -0.8 | | -0.7 | | -3.0 (2.0)
| Loratadine 10 mg | 181/175 | | -0.4 | <0.05 | -0.4 | <0.05 | -0.6 | <0.05 | -0.6 | <0.05 | -1.9 (2.2) | <0.01
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2^c^ | | | | | | | | | -180^e^
| Loratadine 10 mg | 150/150 | | | | | | | | | | -90^e^ | <0.001
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14 | 2^c^ | | | | | | | | | -3.0^e^
| Cetirizine 10 mg | 13 | | | | | | | | | | -1.8^e^ | NS
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14 | 4^d^ | | | | | | | | | -3.7^e^
| Cetirizine 10 mg | 13 | | | | | | | | | | -2.8^e^ | NS

N/n = Number of patients randomized/number of patients analyzed; TNSS = total nasal symptom score.

a All analyses are mean change from baseline.

b All symptom assessments averaged over the treatment duration.

c Analysis compares change from baseline to symptom assessments averaged over the second week of treatment.

d Analysis compares change from baseline to symptom assessments averaged over the fourth week of treatment.

e Calculated by study authors from reported means.

Appendix Table C51 Eye symptom outcomes: change from baseline–combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline | p versus Combo
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169/166 | 2 | Individual symptoms a | NR | NR
| Loratadine 10 mg | 181/175 | | | NR | NR | <0.05
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14 | 2 | TOSS (scale 0-3) | 1.6 | -1^b^
| Cetirizine 10 mg | 13 | | | 2.4 | -1.2^b^ | NS
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14 | 4 | TOSS (scale 0-3) | 1.6 | -1.2^b^
| Cetirizine 10 mg | 13 | | | 2.4 | -1.4^b^ | NS

N/n = Number of patients randomized/number of patients analyzed; NR = not reported; NS = non-significant; TOSS = total ocular symptom score.

a Includes itchy eyes, watery eyes and red eyes, assessed daily by patients on a 0 (no symptoms) to 3 (severe symptoms) scale. With the exception of stating that all symptoms were and were not statistically different from combination therapy, no assessment means or p values were reported.

b Mean differences calculated by study authors.

Appendix Table C52 Quality of life outcomes: combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from Baseline | p versus Combo
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2 | RQLQ^a^ | 4.0 (0.1) | -2.3 (0.1) | <0.001
| Loratadine 10 mg | 150/150 | | | 4.1 (0.1) | -1.3 (0.1)
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2 | Global Assessment^b^ | | 75 | <0.001
| Loratadine 10 mg | 150/150 | | | | 43
Wilson, 2000 | Cetirizine 10 mg/Mometasone furoate 200 mcg | 14/ | 8 | Global Assessment^c^ | NR | NR | NS
| Cetirizine 10 mg | 13/ | | | NR | NR

N/n = Number of patients randomized/number of patients analyzed; NR = not reported; NS = non-siginificant; RQLQ = Rhinitis Quality of Life Questionnaire.

a Scores range from 0 (no impairment) to 6 (severely impaired). The minimum clinically important difference is 0.5 points.

b Patient rated overall response to therapy after two weeks of treatment. Percent reporting moderate or significant improvement. P value describes overall test comparing groups over the full 7 point Likert scale.

c Patients recorded extent to which their symptoms interfered with their daily activity on an 11-point scale (0 = no interference , 10 = maximal interference)

## Combination Oral Selective Antihistamine Plus Intranasal Corticosteroid Versus Intranasal Corticosteroid

Appendix Table C53 Trial description: oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Anolik, 2008 | N.America Multiple | March 1995 2.1 weeks | NR Industry | 345 | Minimum SAR severity and duration | Chronic asthma Immunotherapy Infection Deformities | No | • | • | • | • | •
Barnes, 2006 | Europe Single | June 2004 2 weeks | Academia Industry | 62 | | SAR meds/- Pregnancy Deformities | Yes | • | • | • | • | •
Benincasa, 1994 | Europe Multiple | May 1990 8 weeks | Industry Industry | 454 | Minimum SAR severity and duration | SAR meds/+ Other meds Pregnancy Infection Deformities | Yes | | | | • | •
Di Lorenzo, 2004 | Europe Multiple | April 2001 6 weeks | Health system^b^ NR | 40 | Minimum SAR severity and duration | SAR meds/+ Chronic asthma Pregnancy Infection Deformities | Yes | • | | • | • | •
Ratner, 1998 | N.America Multiple | 2 weeks | Industry Industry | 300 | Minimum SAR severity and duration | SAR meds/+ Pregnancy Infection Deformities | No | • | • | | • | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

b Ministero Italiano Universita` e Ricerca (MIUR).

Appendix Table C54 Patient characteristics: oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N | Mean Age, years | Sex, % female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169 | 26 Range: 11-62 | 50.3 | Unspecified | 14 Range: 2-51 | C: 2.3 R: 2.1 S: 1.8 I: 1.8 TNSS: 7.9 (2.0)
| Mometasone furoate 200 mcg | 176 | 26 Range: 12-71 | 50.6 | Unspecified | 13 Range: 2-56 | C: 2.2 R: 2.1 S: 1.7 I: 1.7 TNSS: 7.8 (2.5)
Barnes, 2006 | Levocetirizine 5 mg/Fluticasone propionate 200 mcg | 31 | 44.9 | 59.3 | Unspecified | | C: 1.24 (0.79) R: 1.00 (0.78) S: 1.31 (0.72) I: 1.16 (0.79) TNSS: 4.56 (2.58)
| Fluticasone propionate 200 mcg | 31 | 44.9 | 59.3 | Unspecified | | C: 1.24 (0.79) R: 1.00 (0.78) S: 1.31 (0.72) I: 1.16 (0.79) TNSS: 4.56 (2.58)
Benincasa, 1994 | Cetirizine 10 mg/Fluticasone propionate 200 mcg | 227 | 30 Range: 12-66 | 56 | Unspecified | <10: 48% >10: 52%
| Fluticasone propionate 200 mcg | 227 | 31 Range: 12-80 | 58 | Unspecified | <10: 46% >10: 54%
Di Lorenzo, 2004 | Cetirizine 10 mg/Fluticasone propionate 200 mcg | 20 | 32.8 Range: 14-48 | 60 | Unspecified | 2-4 years: 55% 5-9 years: 30% 10+ years:15%
| Fluticasone propionate 200 mcg | 20 | 30.5 Range: 15-50 | 40 | Unspecified | 2-4 years: 55% 5-9 years: 25% 10+ years:20%
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150 | 42.2 Range: 15-78 | 51 | White: 80 Hispanic: 17 Other: 3 | | TNSS: 290^b^
| Fluticasone propionate 200 mcg | 150 | 40.7 Range: 13-80 | 55 | White: 78 Hispanic: 15 Other: 7 | | TNSS: 290^b^

C = Congestion; I = itching; n= patients randomized or assigned to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Except as noted, individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms). Scores were summed (maximum individual symptom = 3, maximum TNSS = 12).

b Individual symptoms scored on a 0-100 VAS. TNSS scale is 0-400.

Appendix Table C55 USPSTF quality assessment: oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Anolik, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Barnes, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Benincasa, 1994 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Di Lorenzo, 2004 | No | Yes | Yes | Yes | Yes | Yes | Yes | Poor
Ratner, 1998 | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Fair

USPSTF = United States Preventive Services Task Force.

Appendix Table C56 Nasal symptom outcomes: change from baseline–oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion^a^ | p versus Combo | Rhinorrhea^a^ | p versus Combo | Sneezing^a^ | p versus Combo | Itching^a^ | p versus Combo | TNSS^a^ | p versus Combo
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169/166 | 2^b^ | -0.7 | | -0.7 | | -0.8 | | -0.7 | | -3.0 (2.0)
| Mometasone furoate 200 mcg | 176/166 | | -0.7 | NS | -0.7 | NS | -0.7 | NS | -0.6 | NS | -2.7 (2.5) | NS
Barnes, 2006 | Levocetirizine 5 mg/Fluticasone propionate 200 mcg | 31/27 | 2^c^ | -0.49 (-0.74, -0.24) | | -0.40 (-0.66, -0.14) | | -0.66 (-0.96, -0.36) | | -0.58 (-0.88, -0.28) | | -2.13 (-3.04, -1.23)
| Fluticasone propionate 200 mcg | 31/27 | | -0.60 (-0.63, -0.10) | 0.005 | -0.37 (-0.63, -0.23) | 0.1 | -0.51 (-0.79, -0.23) | 0.54 | -0.55 (-0.85, -0.25) | 0.06 | -2.02 (-2.91, -1.13) | <0.05
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2^c^ | | | | | | | | | -180^e^
| Fluticasone propionate 200 mcg | 150/150 | | | | | | | | | | -150^e^ | <0.05
Di Lorenzo, 2004 | Cetirizine 10 mg/Fluticasone propionate 200 mcg | 20/20 | 6^b^
| Fluticasone propionate 200 mcg | 20/20 | | | NS | | NS | | NS | | 0.003 | f | 0.04
Benincasa, 1994 | Cetirizine 10 mg/Fluticasone propionate 200 mcg | 227/227 | 8^b^ | | | | | | | | | f
| Fluticasone propionate 200 mcg | 227/227 | | | | | | | | | | f | NS

N/n = Number randomized/number analyzed; NS = non-significant; TNSS = total nasal symptom score.

a All analyses are mean change from baseline.

b All symptom assessments averaged over the treatment duration.

c Analysis compares change from baseline to symptom assessments averaged over the second week of treatment.

d Analysis compares change from baseline to symptom assessments averaged over the fourth week of treatment.

e Calculated by study authors from reported means.

f Comparative treatment effects were reported, no treatment level change from baseline provided. See Summary table for comparative treatment effects.

Appendix Table C57 Eye symptom outcomes: change from baseline–oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline | p versus Combo
Anolik, 2008 | Loratadine 10 mg/Mometasone furoate 200 mcg | 169/166 | 2 | Individual symptoms^a^ | NR | NR
| Mometasone furoate 200 mcg | 176/166 | | | NR | NR | ≤0.03
Benincasa, 1994 | Cetirizine 10 mg/Fluticasone propionate 200 mcg | 227/227 | 8 | TOSS (scale 0-10) | | c
| Fluticasone propionate 200 mcg | 227/227 | | | | c | NS

N/n = number randomized/number analyzed; NR = not reported; NS = non-significant; TOSS = total ocular symptom score.

a Includes itchy eyes, watery eyes and red eyes, assessed daily by patients on a 0 (no symptoms) to 3 (severe symptoms) scale. With the exception of stating that all symptoms were and were not statistically different from combination therapy, no assessment means or p-values were reported.

b Mean differences calculated by study authors.

c Comparative treatment effects were reported, no treatment level change from baseline provided. See Summary table for comparative treatment effects.

Appendix Table C58 Quality of life outcomes: change from baseline–oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from Baseline | p versus Combo
Barnes, 2006 | Levocetirizine 5 mg/Fluticasone propionate 200 mcg | 31/27 | 2 | Mini RQLQ^a^ | 2.5 (0.22) | -0.4 | NS
| Fluticasone propionate 200 mcg | 31/27 | | | 2.5 (0.22) | -0.5
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2 | RQLQ^b^ | 4.0 (0.1) | -2.3 (0.1)
| Fluticasone propionate 200 mcg | 150/150 | | | 4.1 (0.1) | -2.2 (0.1) | NS
Ratner, 1998 | Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150 | 2 | Global Assessment^c^ | | 75
| Fluticasone propionate 200 mcg | 150/150 | | | | 71 | NS

N/n = Number randomized/number analyzed; NS = non-significant; RQLQ = Rhinitis Quality of Life Questionnaire.

Values are presented as mean (standard deviation) unless otherwise noted.

a Scores range from 0 (no trouble) to 6 (extremely troubled). Average of 14 questions in 5 domains (activity, practical problems, nose symptoms, eye symptoms and other symptoms).

b Scores range from 0 (no impairment) to 6 (severely impaired). The minimum clinically important difference is 0.5 points.

c Patient rated overall response to therapy after two weeks of treatment. Percent reporting moderate or significant improvement. P value describes overall test comparing groups over the full 7 point Likert scale.

d Patients recorded extent to which their symptoms interfered with their daily activity on an 11-point scale (0 = no interference, 10 = maximal interference).

## Combination Intranasal Corticosteroid Plus Nasal Antihistamine Versus Intranasal Corticosteroid and Nasal Antihistamine

Appendix Table C59 Trial description: combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Rx | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Carr, 2012 (Trial 1) | N.America Multiple | March 2008 2 weeks | Industry Yes | 622 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Carr, 2012 (Trial 2) | N.America Multiple | August 2008 2 weeks | Industry Yes | 576 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Carr, 2012 (Trial 3) | N.America Multiple | April 2009 2 weeks | Industry Yes | 1343 | Minimum SAR severity and duration | SAR meds/- Other meds Chronic asthma Infection Deformities | No | • | • | | • | •
Hampel, 2010 | N.America Multiple | January 2007 2 weeks | Industry Yes | 459 | Minimum SAR severity and duration | SAR meds/- Other meds Infection Deformities | No | • | • | | • | •
Ratner, 2008 | N.America Multiple | December 2005 2 weeks | Industry Yes | 151 | Minimum SAR severity and duration | SAR meds/+ Other meds | No | • | • | • | • | •

N = patients randomized to comparator groups of interest; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C60 Patient characteristics: combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, Year | Drug, Dose/Day | N | Mean Age, years | Sex, % female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Carr, 2012 (Trial 1) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 207 | 37.3 (14.1) | 68.6 | White: 78.3 | 21.7 (13.2) | C: 5.1 (0.8) R: 4.5 (1.0) S: 4.0 (1.3) I: 4.6 (1.0) TNSS: 18.3 (3.0)
| Azelastine 548 mcg | 208 | 36.2 (14.6) | 62.5 | White: 77.9 | 21.6 (13.6) | C: 5.1 (0.8) R: 4.5 (1.2) S: 4.0 (1.3) I: 4.5 (1.2) TNSS: 18.2 (3.5)
| Fluticasone propionate 200 mcg | 207 | 38.6 (14.1) | 61.4 | White: 77.8 | 21.3 (13.5) | C: 5.0 (0.9) R: 4.6 (1.0) S: 4.1 (1.2) I: 4.5 (1.1) TNSS: 18.2 (3.2)
Carr, 2012 (Trial 2) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 193 | 38.8 (14.1) | 65.3 | White: 79.8 | 21.5 (13.5) | C: 5.1 (0.9) R: 4.5 (1.1) S: 4.1 (1.3) I: 4.5 (1.1) TNSS: 18.2 (3.3)
| Azelastine 548 mcg | 194 | 38.2 (13.5) | 66.0 | White: 78.9 | 19.7 (13.1) | C: 5.1 (0.8) R: 4.5 (1.1) S: 4.2 (1.3) I: 4.7 (1.1) TNSS: 18.5 (3.1)
| Fluticasone propionate 200 mcg | 189 | 37.0 (13.6) | 64.0 | White: 74.1 | 21.1 (13.7) | C: 5.0 (0.8) R: 4.6 (1.0) S: 4.2 (1.3) I: 4.8 (0.9) TNSS: 18.6 (2.9)
Carr, 2012 (Trial 3) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 448 | 35.6 (14.5) | 61.8 | White: 81.3 | 20.4 ( 13.0) | C: 5.3 (0.7) R: 4.7 (1.0) S: 4.5 (1.2) I: 4.9 (0.9) TNSS: 19.4 (2.4)
| Azelastine 548 mcg | 445 | 36.4 (14.8) | 60.9 | White: 80.2 | 19.5 (12.9) | C: 5.3 (0.7) R: 4.8 (0.9) S: 4.5 (1.1) I: 4.9 (0.9) TNSS: 19.5 (2.5)
| Fluticasone propionate 200 mcg | 450 | 34.2 (14.5) | 62.2 | White: 79.1 | 19.6 (12.5) | C: 5.3 (0.7) R: 4.8 (0.9) S: 4.5 (1.2) I: 4.9 (0.9) TNSS: 19.4 (2.4)
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153 | 39.5 Range: 12-73 | 63.4 | White: 86.3 Black: 9.8 Asian: 2.6 Other: 1.3 | 18.7 Range: 3-64 | TNSS: 18.8 (9-24)^b^
| Azelastine 548 mcg | 152 | 39.5 Range: 12-74 | 63.8 | White: 88.8 Black: 9.9 Asian: 0.0 Other: 1.3 | 19.0 Range: 2-61 | TNSS: 18.1 (10-24)^b^
| Fluticasone propionate 200 mcg | 153 | 38.1 Range: 12-74 | 66.2 | White: 86.1 Black: 10.6 Asian: 2.0 Other: 1.3 | 18.4 Range: 3-57 | TNSS: 18.3 (8-24)^b^
Ratner, 2008 | Azelastine 8 puffs/Fluticasone propionate 200 mcg | 52 | 36.0 Range: 13-70 | 63.5 | White: 78.8 Black: 3.8 Hispanic: 15.4 Asian: 1.9 Other: 0 | 16.2 Range: 4-40 | C: 5.4 (0.6) R: 4.9 (1.0) S: 4.5 (1.2) I: 4.7 (1.0) TNSS: 19.5 (3.0)
| Azelastine 8 puffs | 49 | 38.4 Range: 12-73 | 55.1 | White: 73.5 Black: 10.2 Hispanic: 14.3 Asian: 0 Other: 2.0 | 19.2 Range: 3-50 | C: 5.5 (0.5) R: 4.9 (0.8) S: 4.5 (1.1) I: 4.8 (0.8) TNSS: 19.7 (2.1)
| Fluticasone propionate 200 mcg | 50 | 37.4 Range: 12-72 | 70.0 | White: 64.0 Black: 4.0 Hispanic: 26.0 Asian: 6.0 Other: 0 | 15.7 Range: 3-51 | C: 5.5 (0.4) R: 5.0 (1.0) S: 4.3 (1.3) I: 4.8 (1.3) TNSS: 19.6 (2.7)

C = Congestion; I = itching; n= patients randomized or assigned to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing; TNSS = total nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) for each individual symptom. Morning and evening scores were summed (maximum individual symptom = 6, maximum TNSS = 24).

b Interquartile range.

Appendix Table C61 USPSTF quality assessment: combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Carr, 2012 (Trial 1) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Carr, 2012 (Trial 2) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Carr, 2012 (Trial 3) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Hampel, 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Ratner, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

USPSTF = United States Preventive Services Task Force.

Appendix Table C62 Nasal symptom outcomes: change from baseline–combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congest^a^ | p vs. Combo | Rhino^a^ | p vs. Combo | Sneeze^a^ | p vs. Combo | Itch^a^ | p vs. Combo | TNSS^a^ | p vs. Combo
Carr, 2012 (Trial 1) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 207/207 | 2 | -1.3 (1.4) | | -1.5 (1.5) | | -1.6 (1.6) | | -1.3 (1.5) | | -5.5 (5.2)
| Azelastine 548 mcg | 208/208 | | -0.9 (1.3) | 0.003 | -1.1 (1.4) | <0.001 | -1.3 (1.3) | 0.010 | -0.9 (1.3) | 0.015 | -4.1 (4.6) | 0.002
| Fluticasone propionate 200 mcg | 207/207 | | -1.2 (1.3) | 0.163 | -1.3 (1.4) | 0.043 | -1.5 (1.4) | 0.144 | -1.3 (1.3) | 0.058 | -5.0 (4.7) | 0.034
Carr, 2012 (Trial 2) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 193/193 | 2 | -1.3 (1.3) | | -1.4 (1.5) | | -1.7 (1.6) | | -1.3 (1.5) | | -5.6 (5.2)
| Azelastine 548 mcg | 194/194 | | -1.0 (1.3) | 0.002 | -1.0 (1.3) | 0.058 | -1.3 (1.5) | 0.066 | -1.1 (1.3) | 0.093 | -4.4 (4.6) | 0.032
| Fluticasone propionate 200 mcg | 189/189 | | -1.1 (1.5) | 0.022 | -1.3 (1.5) | 0.274 | -1.4 (1.5) | 0.046 | -1.2 (1.4) | 0.070 | -5.0 (5.2) | 0.038
Carr, 2012 (Trial 3) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 448/448 | 2 | -1.2 (1.4) | | -1.4 (1.5) | | -1.7 (1.6) | | -1.3 (1.5) | | -5.6 (5.2)
| Azelastine 548 mcg | 445/445 | | -1.0 (1.2) | 0.004 | -1.2 (1.4) | 0.006 | -1.4 (1.5) | 0.012 | -1.1 (1.4) | 0.065 | -4.5 (4.8) | 0.016
| Fluticasone propionate 200 mcg | 450/450 | | -1.1 (1.2) | 0.106 | -1.3 (1.4) | 0.170 | -1.5 (1.5) | 0.014 | -1.2 (1.3) | 0.142 | -5.1 (4.7) | 0.129
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153/153 | 2 | -1.24 | | -1.42 | | -1.47 | | -1.22 | | -5.31 (5.08)
| Azelastine 548 mcg | 152/152 | | -0.75 | <0.01 | -0.87 | <0.01 | -0.86 | <0.01 | -0.82 | <0.05 | -3.25 (4.16) | <0.01
| Fluticasone propionate 200 mcg | 153/151 | | -0.86 | <0.01 | -1.15 | NR | -0.98 | <0.01 | -0.91 | <0.05 | -3.84 (4.76) | <0.01
Ratner, 2008 | Azelastine 8 puffs^b^/Fluticasone propionate 200 mcg | 52/52 | 2 | -1.7 (1.4) | | -1.7 (1.6) | | -2.1 (1.7) | | -1.9 (1.7) | | -7.4 (5.6)
| Azelastine 8 puffs^b^ | 49/49 | | -1.1 (1.5) | 0.02 | -1.1 (1.4) | 0.02 | -1.5 (1.0) | 0.04 | -1.1 (1.4) | 0.009 | -4.8 (4.3) | 0.008
| Fluticasone propionate 200 mcg | 50/49 | | -1.1 (1.2) | 0.04 | -1.3 (1.2) | 0.19 | -1.5 (1.5) | 0.05 | -1.3 (1.5) | 0.02 | -5.2 (4.6) | 0.03

a All analyses are mean change from baseline over the entire treatment duration.

b Symptoms score twice daily 0 (no symptoms) to 3 (severe symptoms); maximum daily score for individual symptom = 6, for TNSS = 24.

c Equivalent to 548 mcg/day

Appendix Table C63 Eye symptom outcomes: change from baseline––combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline | p vs. Combo
Carr, 2012 (Trial 1) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 207/207 | 2 | TOSS (scale 0-18) | 11.9 (3.9) | -3.2 (4.0)
| Azelastine 548 mcg | 208/208 | | | 11.5 (4.5) | -2.8 (3.8) | 0.457
| Fluticasone propionate 200 mcg | 207/207 | | | 11.4 (4.4) | -2.6 (3.5) | 0.097
Carr, 2012 (Trial 2) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 193/193 | 2 | TOSS (scale 0-18) | 11.7 (4.2) | -3.6 (3.9)
| Azelastine 548 mcg | 194/194 | | | 11.8 (3.9) | -3.0 (3.3) | 0.069
| Fluticasone propionate 200 mcg | 189/189 | | | 12.0 (3.8) | -2.7 (3.6) | 0.009
Carr, 2012 (Trial 3) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 448/448 | 2 | TOSS (scale 0-18) | 12.3 (4.0) | -3.0 (4.0)
| Azelastine 548 mcg | 445/445 | | | 12.4 (4.0) | -3.0 (3.8) | 0.912
| Fluticasone propionate 200 mcg | 450/450 | | | 12.3 (3.6) | -2.8 (3.5) | 0.247
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153/153 | 2 | TOSS (scale 0-18) | | -3.33
| Azelastine 548 mcg | 152/152 | | | | -2.62 | NR
| Fluticasone propionate 200 mcg | 153/151 | | | | -2.17 | <0.01

N/n, number randomized/number analyzed

a Three symptoms (itchy eyes, watery eyes, red eyes) each scored twice daily on a 0 (no symptoms) to 3 (severe symptoms) scale; maximum daily score = 18.

b Mean differences adjusted for center, day, and baseline symptoms.

c Mean differences calculated by study authors.

Appendix Table C64 Quality of life outcomes: change from baseline–combination nasal selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid and nasal antihistamine

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from Baseline | p vs. Combo
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153/153 | 2 | RQLQ | | 1.60
| Azelastine 548 mcg | 152/152 | | | | 1.17 | 0.005
| Fluticasone propionate 200 mcg | 153/151 | | | | 1.43 | 0.29
Ratner, 2008 | Azelastine 8 puffs/Fluticasone propionate 200 mcg | 52/52 | 2 | RQLQ | 3.93 (1.09) | 1.92 (1.46)
| Azelastine 8 puffs | 49/49 | | | 3.66 (1.13) | 1.21 (1.02) | 0.005
| Fluticasone propionate 200 mcg | 50/49 | | | 3.95 (1.14) | 1.47 (1.21) | 0.08

## Combination Oral Selective Antihistamine Plus Oral Decongestant Versus Oral Selective Antihistamine

Appendix Table C65 Trial description: combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, Year | Location, Site(s) | Enrollment/Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria | Rescue Medication Use | Objective Diagnosis | Run in Period | Pollen Count | Patient Blinding | Assessor Blinding
Bronsky, 1995 | N.America Multiple | Fall 1989 2 weeks | Industry Yes | 438 | Minimum SAR severity and duration | SAR meds Other meds Chronic asthma Pregnancy Infection | No | • | • | • | • | •
Chervinsky, 2005 | N.America Multiple | 2 weeks | NR Yes | 428 | Minimum SAR severity and duration | SAR meds Pregnancy Infection | No | • | • | • | • | •
Grosclaude, 1997 | Europe Multiple | March1992 2 weeks | NR Yes | 458 | Minimum SAR severity and duration | SAR meds Other meds Pregnancy Infection Deformities | Yes | • | | • | • | •
Grubbe, 2009 | N.America Multiple | 2.1 weeks | Industry Yes | 398 | Minimum SAR severity and duration | SAR meds Chronic asthma Pregnancy Infection Deformities | No | • | • | • | • | •
Pleskow, 2005 | N.America Multiple | 2000 2 weeks | Industry Yes | 744 | Minimum SAR severity and duration | SAR meds Pregnancy Infection Deformities | No | • | • | • | • | •
Schenkel, 2002 | N.America Multiple | 2.1 weeks | Industry NR | 676 | Minimum SAR duration | SAR meds Chronic asthma Pregnancy | No | • | • | | • | •
Sussman, 1999 | N.America Multiple | 2.4 weeks | Industry Yes | 433 | Minimum SAR severity | SAR meds Pregnancy Infection | No | • | • | • | • | •

N = patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

Appendix Table C66 Patient characteristics: combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N | Mean Age, years | Sex, % female | Race, % | Disease Duration, years | Mean Baseline NSS^a^
Bronsky, 1995 | Loratadine 10 mg/Pseudoephedrine 240 mg | 221 | Median: 30 Range: 12-82 | 53.8 | White: 87.3 Black: 5.7 Other: 7.1 | Median: 15 Range: 2-47
| Loratadine 10 mg | 217 | Median: 30 Range: 12-60 | 57.5 | White: 87.3 Black: 4.2 Other: 8.5 | Median: 15 Range: 1-50
Chervinsky, 2005 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 214 | 36 | 64 | Unspecified | 18 | C: 2.55
| Desloratadine 5 mg | 214 | 37 | 69 | Unspecified | 19 | C: 2.56
Grosclaude, 1997 | Cetirizine 10 mg/Pseudoephedrine 240 mg | 227 | 31 Range: 9-65 | 47 | Unspecified | 9 | C: 2.29 R: 1.99 S: 1.93 I: 1.71
| Cetirizine 10 mg | 231 | 32 Range: 12-66 | 52 | Unspecified | 8 | C: 2.28 R: 2.07 S: 2.02 I: 1.76
Grubbe, 2009 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 200 | 34.9 Range: 12-74 | 60.5 | White: 81 Black: 12 Hispanic: 4 Asian: 2 Other: 2 | 19.6 Range: 2-69 | C: 2.47
| Desloratadine 5 mg | 198 | 37 Range: 12-76 | 65.2 | White: 77 Black: 13 Hispanic: 7 Asian: 2 Other: 2 | 17.9 Range: 2-56 | C: 2.50
Pleskow, 2005 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 372 | 34 Range: 12-78 | 59.4 | White: 77 Black: 11 Hispanic: 8 Asian: 3 Other: <1 | 16.5 Range: 2-51
| Desloratadine 5 mg | 372 | 35 Range: 12-76 | 65.9 | White: 80 Black: 12 Hispanic: 7 Asian: <1 Other: 0 | 18.0 Range: 2-55
Schenkel, 2002 | Desloratadine 5 mg Pseudoephedrine 240 mg | 336 | 34.2 | 64 | Unspecified | 17.5 | C: 2.56
| Desloratadine 5 mg | 340 | 34.8 | 60 | Unspecified | 18.3 | C: 2.57
Sussman, 1999 | Fexofenadrine 120 mg/Pseudoephedrine 240 mg | 215 | 33.0 (11.41) Range: 13-66 | 57.7 | White: 86.5 Black: 6.0 Asian: 5.6 Other: 1.9 | 14.9 (9.65) Range: 2.0-55.0 | C: 2.32 (SE: 0.03)
| Fexofenadrine 120 mg | 218 | 34.9 ( 12.35) Range: 12-64 | 56.9 | White: 85.3 Black: 6.0 Asian: 8.3 Other: 0.5 | 15.2 (9.79) Range: 2.0-46.2 | C: 2.36 (SE: 0.03)

C = Congestion; I = itching; n= patients randomized to comparator groups of interest; NSS = nasal symptom score; R = rhinorrhea; S = sneezing, SE = standard error.

Values are presented as mean (standard deviation) unless otherwise noted.

a Individual symptoms rated on a scale from 0 (no symptoms) to 3 (severe symptoms) in all cases except Sussman (1999) where the maximum was 4.

Appendix Table C67 USPSTF quality assessment: combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Bronsky, 1995 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Chervinsky, 2005 | Yes | Uncertain | Yes | Yes | Yes | Yes | No | Poor
Grosclaude, 1997 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Grubbe, 2009 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Pleskow, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | No | Poor
Schenkel, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Sussman, 1999 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Appendix Table C68 Nasal symptom outcomes: change from baseline–combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congest^a^ | p | Rhino^a^ | p | Sneeze^a^ | p | Itch^a^ | p | TNSS^a^ | p
Bronsky, 1995 | Loratadine 10 mg/Pseudoephedrine 240 mg | 221/212 | 2 | -0.7 | | | | | | | | -2.9 | NR
| Loratadine 10 mg | 217/212 | | -0.5 | ≤0.02 | | | | | | | -2.3
Chervinsky, 2005 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 214/200 | 2 | -0.92
| Desloratadine 5 mg | 214/200 | | -0.73
Grosclaude, 1997 | Cetirizine 10 mg/Pseudoephedrine 240 mg | 227/227 | 2 | -1.1 | <0.001 | -1.09^b^ | <0.001 | -1.19^b^ | <0.01 | -0.96^b^ | <0.01
| Cetirizine 10 mg | 231/231 | | -0.85^b^ | | -0.96^b^ | | -1.11^b^ | | -0.86^b^
Grubbe, 2009 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 200 | 2 | -0.93 | <0.001
| Desloratadine 5 mg | 198^c^ | | -0.66
Pleskow, 2005 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 372^c^ | 2 | -0.9 | ≤0.001
| Desloratadine 5 mg | 372^c^ | | -0.74
Schenkel, 2002 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 336/336 | 2 | 0.85 | <0.001
| Desloratadine 5 mg | 340/340 | | 0.65
Sussman, 1999 | Fexofenadrine 120 mg/Pseudoephedrine 240 mg | 215/215 | 2.6 | -0.6^d^ | 0.0005 | -0.5^d^ | NR | -0.6 | NR
| Fexofenadrine 120 mg | 218/218 | | -0.4^d^ | | -0.4^d^ | | -0.5^d^

N/n, number randomized/number analyzed

a Mean change from baseline over the entire treatment duration

b Calculated by author using pre/post data

c Only patient randomized are reported

d Values obtained using Engauge Digitizer Software

Appendix Table C69 Eye symptom outcomes: change from baseline–combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | Change from baseline | p
Grosclaude, 1997 | Cetirizine 10 mg/Pseudoephedrine 240 mg | 227/227 | 2 | Itching eyes | 1.68 | -1.01^a^
| Cetirizine 10 mg | 231/231 | | | 1.83 | -1.02 a | NS
Sussman, 1999 | Fexofenadrine 120 mg/Pseudoephedrine 240 mg | 215/215 | 2.6 | Itchy, watery, red eyes | NR | -0.6 b,c
| Fexofenadrine 120 mg | 218/218 | | | NR | -0.5 b,c | NR

N/n, number randomized/number analyzed

a 4-point scale: 0, absent; 1, mild; 2, moderate; 3, severe.

b 5-point scale: 0, absent; 1, mild; 2, moderate; 3, severe; 4, very severe

c Values obtained using Engauge Digitizer Software

Appendix Table C70 Quality of life outcomes: change from baseline–combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, year | Drug, Dose/Day | N/n | Time, weeks | Outcome | Baseline mean | End of treatment | p
Bronsky, 1995 | Loratadine 10 mg/Pseudoephedrine 240 mg | 221/212 | 2 | % patients reporting good or excellent response to treatment^a^ | | 61^b^ | 0.004^d^
| Loratadine 10 mg | 217/212 | | | | 47^c^

a 5 point scale: 1, excellent; 2, good; 3, fair; 4, poor; 5, treatment failure

b 125/204

c 95/203

d P-value calculated by report author, chi-square test.

## Comparative Harms

Appendix Table C71 Comparative harms: oral selective antihistamine versus oral nonselective antihistamine

Author, Year | Treatment Group | N/n | Sedation | Headache
Dockhorn, 1987 | Loratadine 10 mg | 111/108 | MOD: 6.3 | MOD: 10.8
| | | SEV: 0
| Clemastine 2 mg | 109/105 | MOD: 19.3 | MOD: 9.2
| | | SEV: 2.8
Harvey, 1996 | Cetirizine 5-10mg | 43/39 | 11.6
| Chlorpheniramine 16mg | 43/40 | 40.5
Kemp, 1987 | Loratadine 10 mg | 108/108 | 15 | 11.3
| Clemastine 2 mg | 101/101 | 23 | 6.8

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

Appendix Table C72 Comparative harms: oral selective antihistamine versus nasal selective antihistamine

Author, year | Treatment Group | N/n | Sedation | Headache | Nasal Discomfort | Bitter Aftertaste | Hypertension | Insomnia | Nosebleeds
Berger, 2003 a | Desloratadine 5mg b | 111/111 | 1 | 3 | | 0
| Azelastine 4 puffs/nostril^c^ | 108/106 | 2 | 0 | | 11
Berger, 2006 | Cetirizine 10mg | 175/175 | SEV: 0 | SEV: 0 | | | SEV: 0
| | | 2 | 2 | | 0 | | | 2
| Azelastine 4 puffs/nostril | 179/179 | SEV: 0.6 | SEV: 0.6 | | | SEV: 0.6
| | | 2 | 2 | | 7.7 | | | 2
Charpin, 1995 | Cetirizine 10mg | 69^b^ | SEV: 1
| | | 7 | 1
| Azelastine 2 puffs/nostril | 67^b^ | 2 | 1
Corren, 2005 | Cetirizine 10mg | 155/155 | SEV: 0.6
| | | 1.9 | 1 | 1 | 1 | | | 1
| Azelastine 4 puffs/nostril | 152/151 | | | | | | SEV: 0.7
| | | 1.3 | 2.6 | 1.3 | 3.3 | | | 2
Gambardella, 1993 | Loratadine 10mg^d^ | 15 | SEV: 0
| Azelastine 560 mcg^e^ | 15 | SEV: 6.7

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Other: Chest pain: 0.9, Lightheadedness: 0.9.

b 4 discontinuations due to events (headache, pregnancy, cough, elevated blood pressure, fatigue).

c 1 AE discontinuation (vomiting and GI distress).

d Paper reported that adverse events were not serious but nasal congestion in this group caused 1 person to withdraw from study.

e Paper reported that adverse events were not serious but epigastralgia and urticaria in this group caused 1 person to withdraw from study.

Appendix Table C73 Comparative harms: oral selective antihistamine versus intranasal corticosteroids

Author, Year | Treatment Group | N/n | Sedation | Headache | Atrophy | Burning | Anxiety | Nosebleeds | Odor | Fungal
Anolik, 2008 | Loratadine 10 mg | 181/175 | MOD: 2 | MOD: 8 | | MOD: 0 | | MOD:1
| Mometasone furoate 200 mcg | 176/166 | MOD: 1 | MOD: 6 | | MOD: 0 | | MOD: 1
Bernstein, 2004 | Loratadine 10 mg | 158 | | 18
| Fluticasone propionate 200 mcg | 158 | | 17
Condemi, 2000 | Loratadine 10 mg^a^ | 174 | | 15.3
| Triamcinolone acetonide 220 mcg^b^ | 174 | | 14.3
Gawchik, 1997 | Loratadine 10 mg | 150/150 | | 18 | | | MOD: NR | MILD: NR
| Triamcinolone acetonide 220 mcg | 150/150 | | 22 | | | MOD: 0.7 | MILD: 0.7
Jordana, 1996 | Loratadine 10 mg^c^ | 119/119 | | 25 | 0 | | | 4 | | 0
| Fluticasone propionate 200 mcg^d^ | 121/121 | | 42 | 0 | | | 7 | | 0
Ratner, 1998 e | Loratadine 10 mg | 150/150 | | | | | | ≤1
| Fluticasone propionate 200 mcg | 150/150
Schoenwetter, 1995 | Loratadine 10 mg | 149/140 | | 35
| Triamcinolone acetonide 220 mcg | 149/134 | | 43
Vervloet, 1997 f | Cetirizine 10 mg | 118 | 5.1 | | | | | | 0.8
| Fluticasone propionate 200 mcg | 120 | | | | | | 0.8

N/n = Number of patients randomized/number of patients analyzed; NR = not reported.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a 4 patients discontinued the study. They reported 6 adverse events; three of these events (headache, rhinitis, and chest pain) were classified as possibly or probably related to study drug and occurred in one patient.

b Three loratadine patients withdrew due to adverse events. They reported one adverse event each, none of which were related to study drug.

c Headache separated out as mild/mod/severe but they are n reports, not n patients. There were statistically more headache in Fluticasone propionate group (p=0.003, test type not specified).

d Headache separated out as mild/mod/severe but they are n reports, not n patients. There were statistically more headache in Fluticasone propionate group (p=0.003, test type not specified).

e Adverse events not reported by treatment group.

f Number of reports.

Appendix Table C74 Comparative harms: oral selective antihistamine versus oral decongestant

Author, Year | Treatment Group | N/n | Sedation | Headache | Palpitations | Insomnia | Anxiety
Bronsky, 1995 | Loratadine 10 mg | 217/212 | 4 | 23 | | 1 | 1
| Pseudoephedrine 240 mg | 220/211 | 5 | 26 | | 9 | 4
Chervinsky, 2005 a | Desloratadine 5 mg | 214/200 | | 8 | | 2
| Pseudoephedrine 240 mg | 222/204 | | 6 | | 11
Grosclaude, 1997 | Cetirizine 10 mg | 231/231 | 6.1 | 4.3 | | 0 | 0
| Pseudoephedrine 240 mg | 226/226 | 3.1 | 7.1 | | 11.1 | 2.2
Grubbe, 2009 | Desloratadine 5 mg b,c | 198 | | 7.1 | | 3.0
| Pseudoephedrine 240 mg^d,e^ | 200 | | 12.0 | | 14.0
Pleskow, 2005 | Desloratadine 5 mg | 372 | 4 | 6 | 1 | 1 | 1
| Pseudoephedrine 240 mg | 377 | 5 | 6 | 3 | 7 | 3
Schenkel, 2002 f | Desloratadine 5 mg | 340/340 | 2.1 | 1.5 | | 0.6 | 0.6
| Pseudoephedrine 240 mg | 342/342 | 2.0 | 3.2 | | 7.9 | 0.9
Sussman, 1999 g | Fexofenadrine 120 mg | 218/218 | 0 | 7.3 | 0 | 1.8 | 0
| Pseudoephedrine 240 mg | 218/218 | 1.4 | 12.4 | 2.8 | 12.8 | 1.4

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Unclear if proportions of patients, or reports.

b Other: no increased heart rate reported.

c No serious or unexpected adverse events reported; 9 patients discontinued due to adverse events.

d Other: increased heart rate: 3.0 BPM.

e No serious or unexpected adverse events reported; 4 patients discontinued due to adverse events.

f Number of reports.

g Number of reports.

Appendix Table C75 Comparative harms: oral selective antihistamine versus leukotriene receptor antagonist

Author, year | Treatment Group | N/n | Headache
Baena-Cagnani, 2003 | Desloratadine 5mg | 311 | 3.5
| Montelukast 10mg | 311 | 3.5
Nayak, 2002 | Loratadine 10mg | 155 | 3
| Montelukast 10mg | 301 | 4
Meltzer, 2000 | Loratadine 10mg | 92/90 | 8.7
| Montelukast 10mg | 95/94 | 5.3
Philip, 2002 | Loratadine 10mg | 602 | 3.5
| Montelukast 10mg | 348 | 3.2

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

Appendix Table C76 Comparative harms: intranasal corticosteroids versus nasal selective antihistamine

Author, Year | Treatment Group | N/n | Sedation | Headache | Dryness | Burning | Nasal Discomfort | Bitter Aftertaste | Nosebleeds
Carr, 2012 (Trial 1) | Fluticasone propionate 200mcg | 207/207 | | 2.4 | | | 1 | 1 | 2.4
| Azelastine 548mcg | 208/208 | | 0.5 | | | 1.9 | 3.4 | 1
Carr, 2012 (Trial 2) | Fluticasone propionate 200mcg | 189/189 | | 2.1 | | | 0 | 0.5 | 1.6
| Azelastine 548mcg | 194/194 | | 2.1 | | | 1 | 7.2 | 1.6
Carr, 2012 (Trial 3) | Fluticasone propionate 200mcg | 450/450 | 0 | 1.3 | | | | 0.2 | 1.1
| Azelastine 548mcg | 445/445 | 0.4 | 2 | | | | 5 | 1.1
Ghimire, 2007 | Azelastine 1120mcg | 25 | | | 4 | 4 | 16 | 4
| Beclomethasone dipropionate 400mcg | 25 | | | 12 | 0 | 8 | 0
Hampel, 2010 | Azelastine 548mcg | 152/152 | 0.7 | 1.3 | | | 0 | 2 | 2
| Fluticasone propionate 200mcg | 153/153 | 0.7 | 3.9 | | | 0.7 | 0 | 3.9
Kaliner, 2009 | Olopatadine 4 puffs/nostril | 65/65 | 1.5 | | | | | 3.1 | 4.6
| Fluticasone propionate 200mcg^a^ | 65/65 | 0 | | | | | 0 | 0
Newson-Smith, 1997 | Azelastine 1120mcg^b,c^ | 83 | | 2.4 | | 1.2 | 0 | 6 | 2.4
| Beclomethasone dipropionate 400mcg^d,e^ | 83 | | 7.2 | | 2.4 | 1.2 | 0 | 1.2
Ratner, 2008 f | Azelastine 4 puffs/nostril | 49/49 | | 4.1 | | | | 8.2
| Fluticasone propionate 200mcg | 50/49 | | 4 | | | | 2

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Other: Ocular injection: 1.5.

b Number of reports. Only bitter aftertaste considered tx-related.

c Other: Loss of smell: 0.

d Number of reports.

e Other: Loss of smell: 1.2.

f Sample of reports.

Appendix Table C77 Comparative harms: intranasal corticosteroid versus nasal cromolyn

Author, year | Treatment Group | N/n | Sedation | Headache | Stinging | Dryness | Burning | Nasal Discomfort | Bitter Aftertaste | Nosebleeds
Bjerrum, 1985 | Budesonide 400 mcg | 22/21 | | MILD: 4.5 | | MILD: 4.5 | | MILD: 0 | | MILD: 4.5
| | 22/21 | | SEV: 4.5 | | | | SEV: 14.3 | | SEV: 4.5
| Cromolyn 26 mg | 21/21 | | MILD: 0 | | MILD: 19 | | MILD: 14.3 | | MILD: 0
| | 21/21 | | | SEV: 19 | | SEV: 14.3
Bousquet, 1993 a | Fluticasone propionate 200 mcg | 110/73 | | | | | 1.4 | 2.7
| Cromolyn 20.8 mg | 108/87 | | | | 1.1 | | 1.1
Lange, 2005 b | Mometasone furoate 200 mcg | 41/40 | 2.4 | 43.9 | | | | 7.3
| Cromolyn 22.4 mg | 42/42 | 0 | 40.5 | | | | 11.9
Welsh, 1987 | Cromolyn 41.6 mg | 30/28 | | 16.7 | | 0 | 0 | 3.3 | | 3.3
| Flunisolide 200 mcg | 30/30 | | 3.3 | 26.7 | 3.3 | 3.3 | | 0 | 0
| Beclomethasone dipropionate 336 mcg | 30/28 | | 16.7 | 0 | 0 | 3.3 | 3.3 | | 0

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Number of reports.

b Percent of events, not patients.

Appendix Table C78 Comparative harms: intranasal corticosteroid versus leukotriene receptor antagonist

Author, Year | Treatment Group | N/n | Headache | Palpitations | Anxiety | Nosebleeds
Martin, 2006 | Fluticasone propionate 200 mcg | 367/364 | MOD: 4 | | | MOD: 3
| | | | SEV: 0.3 | SEV: 0.3
| Montelukast 10 mg | 369/366 | MOD: 6 | | | MOD: 4
| | | SEV: 0.3 | SEV: 0
Nathan, 2005 | Fluticasone propionate 200 mcg^a^ | 291/291 | 9 | | | 3
| Montelukast 10 mg^b^ | 282/282 | 14 | | | 2
Ratner, 2003 | Fluticasone propionate 200 mcg^c^ | 353/353 | MOD: 5 | | | MOD: 2
| Montelukast 10 mg^c^ | 352/352 | MOD: 7 | | | MOD: 1

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Adrenal: geometric mean urinary cortisol @ week 4 = 15.67 mcg/24h (n=58).

b Adrenal: geometric mean urinary cortisol @ week 4 = 11.99 mcg/24h (n=51).

c Nasal signs and symptoms were not captured as adverse events. Most adverse events reported were mild to moderate Sample, these are adverse events reported in >1% in either group. No deaths or serious AEs reported (discontinuations not broken down by treatment allocations).

Appendix Table C79 Comparative harms: combination oral selective antihistamine plus intranasal corticosteroid versus intranasal corticosteroid

Author, Year | Treatment Group | N/n | Sedation | Headache | Burning | Nosebleeds
Anolik, 2008 | Mometasone furoate 200 mcg/Loratadine 10 mg | 169/169 | MOD: 2 | MOD: 4 | MOD: 2 | MOD: 4
| Mometasone furoate 200 mcg | 176/176 | MOD: 1 | MOD: 6 | MOD: 0 | MOD: 1
Barnes, 2006 | Fluticasone propionate 200 mcg | 31/27 | 3.7
| Fluticasone propionate 200 mcg/Levocetirizine 5 mg | 31/27 | | | | MILD: 3.7
Benincasa, 1994 a | Fluticasone propionate 200 mcg | 227/227 | SEV: 0.9 | SEV: 0.4
| Fluticasone propionate 200 mcg/Cetirizine 10 mg | 227/227 | SEV: 1.3 | SEV: 0.4 | | SEV: 0.4
Ratner, 1998 | Loratadine 10 mg | 150/150 | | | | ≤1^b^
| Fluticasone propionate 200 mcg | 150/150
| Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Number of reports.

b Across all treatment groups. Adverse events are not otherwise broken down by group.

Appendix Table C80 Comparative harms: combination oral selective antihistamine plus intranasal corticosteroid versus oral selective antihistamine

Author, Year | Treatment Group | N/n | Sedation | Headache | Burning | Nosebleeds
Anolik, 2008 | Mometasone furoate 200 mcg/Loratadine 10 mg | 169/166 | MOD: 2 | MOD: 4 | MOD: 2 | MOD: 4
| Loratadine 10 mg | 181/175 | MOD: 2 | MOD: 8 | MOD: 0 | MOD: 1
Benincasa, 1994 a | Fluticasone propionate 200 mcg | 227/227 | SEV: 1.3 | SEV: 0.4 | | SEV: 0.4
| Fluticasone propionate 200 mcg/Cetirizine 10 mg | 227/227
Ratner, 1998 | Loratadine 10 mg | 150/150 | | | | ≤1^b^
| Fluticasone propionate 200 mcg | 150/150
| Loratadine 10 mg/Fluticasone propionate 200 mcg | 150/150

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Number of reports.

b Across all treatment groups. Adverse events are not otherwise broken down by group.

Appendix Table C81 Comparative harms: combination intranasal corticosteroid plus nasal antihistamine versus intranasal corticosteroid

Author, Year | Drug, Dose/Day | N/n | Sedation | Headache | Nasal Discomfort | Bitter Aftertaste | Nosebleeds
Carr, 2012 (Trial 1) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 207/207 | | 0.5 | 1 | 2.4 | 1
| Fluticasone propionate 200 mcg | 207/207 | | 2.4 | 1 | 1 | 2.4
Carr, 2012 (Trial 2) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 193/193 | | 2.6 | 0.5 | 2.1 | 1.5
| Fluticasone propionate 200 mcg | 189/189 | | 2.1 | 0 | 0.5 | 1.6
Carr, 2012 (Trial 3) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 448/448 | 1.1 | 1.3 | | 4.7 | 1.8
| Fluticasone propionate 200 mcg | 450/450 | 0 | 1.3 | | 0.2 | 1.1
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153/153 | 0.7 | 2.6 | 1.3 | 7.2 | 3.9
| Fluticasone propionate 200 mcg | 153/153 | 0.7 | 3.9 | 0.7 | 0 | 3.9
Ratner, 2008 a | Azelastine 8 puffs/Fluticasone propionate 200 mcg | 52/52 | | 5.8 | | 13.5
| Fluticasone propionate 200 mcg | 50/49 | | 4 | | 2

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Sample of reports.

Appendix Table C82 Comparative harms: combination intranasal corticosteroid plus nasal antihistamine versus nasal antihistamine

Author, Year | Drug, Dose/Day | N/n | Sedation | Headache | Nasal Discomfort | Bitter Aftertaste | Nosebleeds
Carr, 2012 (Trial 1) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 207/207 | | 0.5 | 1 | 2.4 | 1
| Azelastine 548 mcg | 208/208 | | 0.5 | 1.9 | 3.4 | 1.9
Carr, 2012 (Trial 2) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 193/193 | | 2.6 | 0.5 | 2.1 | 1.5
| Azelastine 548 mcg | 194/194 | | 2.1 | 1 | 7.2 | 1.6
Carr, 2012 (Trial 3) | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 448/448 | 1.1 | 1.3 | | 4.7 | 1.8
| Azelastine 548 mcg | 445/445 | 0.4 | 2 | | 5.1 | 1.1
Hampel, 2010 | Azelastine 548 mcg/Fluticasone propionate 200 mcg | 153/153 | 0.7 | 2.6 | 1.3 | 7.2 | 3.9
| Azelastine 548 mcg | 152/152 | 0.7 | 1.3 | 0 | 2 | 2.6
Ratner, 2008 a | Azelastine 8 puffs/Fluticasone propionate 200 mcg | 52/52 | | 5.8 | | 13.5
| Azelastine 8 puffs | 49/49 | | 4.1 | | 8.2

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Sample of reports.

Appendix Table C83 Comparative harms: combination oral selective antihistamine plus oral decongestant versus oral selective antihistamine

Author, Year | Treatment Group | N | Sedation | Headache | Palpitations | Insomnia | Anxiety | Other: Chest Pain
Bronsky, 1995 | Loratadine 10 mg/Pseudoephedrine 240 mg | 221/212 | 6 | 25 | | 5 | 5
| Loratadine 10 mg | 217/212 | 4 | 23 | | 1 | 1
Chervinsky, 2005 a | Desloratadine 5 mg/Pseudoephedrine 240 mg | 214/200 | | 8 | | 10
| Desloratadine 5 mg | 214/200 | | 8 | | 2
| Pseudoephedrine 240 mg | 222/204 | | 6 | | 11
Grosclaude, 1997 | Cetirizine 10 mg/Pseudoephedrine 240 mg | 230/230 | 6.1 | 4.3 | | 0 | 0
| Cetirizine 10 mg | 231/231 | 3.1 | 7.1 | | 11.1 | 2.2
Grubbe, 2009 | Desloratadine 5 mg/Pseudoephedrine 240 mg^b,c^ | 200 | | 6.5 | | 9.5
| Desloratadine 5 mg^d,e^ | 198 | | 7.1 | | 3.0
Pleskow, 2005 | Desloratadine 5 mg/Pseudoephedrine 240 mg | 372 | 6 | 5 | 1 | 5 | 2
| Desloratadine 5 mg | 372 | 4 | 6 | 1 | 1 | 1
Schenkel, 2002 f | Desloratadine 5 mg/Pseudoephedrine 240 mg | 336/336 | 3 | 3 | | 4.8 | 2.7 | 0.3^g^
| Desloratadine 5 mg | 340/340 | 2.1 | 1.5 | | 0.6 | 0.6
Sussman, 1999 h | Fexofenadrine 120 mg/Pseudoephedrine 240 mg | 215/215 | 0 | 7.3 | 0 | 1.8 | 0
| Fexofenadrine 120 mg | 218/218 | 1.4 | 12.4 | 2.8 | 12.8 | 1.4

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

a Unclear if proportions of patients, or reports.

b Other: Increased heart rate 3.9 BPM.

c No serious or unexpected adverse events reported; 7 patients discontinued due to adverse events.

d Other: no increased heart rate reported.

e No serious or unexpected adverse events reported; 9 patients discontinued due to adverse events.

f Number of reports.

g Assigned Severe category by abstractor.

h Number of reports.

Appendix Table C84 Comparative harms: pediatric oral nonselective antihistamine versus oral selective antihistamine

Author, Year | Treatment Group | N/n | Sedation | Headache | Nosebleeds
Tinkelman, 1996 | Cetirizine 10 mg | 62/62 | MOD: 3.6 | MOD: 3.2
| Chlorpheniramine 2 mg | 63/63 | MOD: 7.9 | MOD: 6.3
Boner, 1989 | Loratadine 5 mg | 21 | | | MOD: 9.5
| | | 0
| Dexchlorpheniramine 3 mg | 19 | | | MILD: 10.5
| | | 21.1

N/n = Number of patients randomized/number of patients analyzed.

Symptom severity is unspecified unless otherwise noted (MILD, MOD = moderate, or SEV = severe).

## Comparative Effectiveness and Harms of SAR Treatments in Children Younger Than 12 Years of Age

Appendix Table C85 Trial description: oral selective antihistamine versus oral nonselective antihistamine in children

Author, Year | Location/Site(s) | Enrollment/ Treatment Duration | Funding/Author Industry Disclosures | N | Inclusion Criteria | Exclusion Criteria^a^ | Rescue Medication Use | Objective Diagnosis | Run-in \Period | Pollen Counts Measured | Patient Blinding | Assessor Blinding
Tinkelman, 1996 | N. America Multiple | 2 weeks | Industry NR | 126 | Minimum SAR severity | SAR meds/NR Other meds Infection Deformities | No | • | | | Open Label trial
Boner, 1989 | Europe | April 1986 2 weeks | Industry Yes | 40 | Minimum SAR severity | SAR meds/- Chronic asthma Immunotherapy Deformities | No | • | | •

N = Patients randomized to comparator groups of interest; NR = not reported; SAR = seasonal allergic rhinitis.

a +, -, or NR indicates whether FDA-recommended washout periods were required (+), were not required (-), or were not reported (NR) for restricted SAR medications prior to trial entry.

Appendix Table C86 Patient characteristics: oral selective antihistamine versus oral nonselective antihistamine in children

Author, Year | n | Drug, Dose/Day | Mean Age, years | Sex, % Female | Race, % | Mean Disease Duration, years | Mean Baseline NSS
Tinkelman, 1996 | 126 | Cetirizine 10 mg^a^ | 8.6 Range: 6-11 | 35.5 | White: 87.1 Other: 12.9 | 5.8 (2.6) | NR
| | Chlorpheniramine 2 mg | 8.7 Range: 6-11 | 30.2 | White: 77.8 Other: 22.2 | 5.2 (2.6) | NR
Boner, 1989 | 40 | Loratadine 5 mg^a^ | 7.6 (2.9) | 33.3 | Unspecified | 3.2 (1.3) | NR
| | Dexchlorpheniramine 3 mg^a^ | 7.8 (3.0) | 36.8 | Unspecified | 2.5 (1.8) | NR

n = Patients randomized to comparator groups of interest; NR = not reported; NSS = nasal symptom score.

Values are presented as mean (standard deviation) unless otherwise noted.

a Doses were determined based on body weight.

Appendix Table C87 USPSTF quality assessment: oral selective antihistamine versus oral nonselective antihistamine in children

Author, year | Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results | Overall USPSTF rating
Tinkelman, 1996 | Yes | Yes | Yes | No | Yes | Uncertain | No | Poor
Boner, 1989 | No | Uncertain | Yes | No | Yes | Yes | No | Poor

USPSTF = United States Preventive Services Task Force.

Appendix Table C88 Nasal symptom outcomes: change from baseline–oral selective antihistamine versus oral nonselective antihistamine in children

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Congestion | p | Sneezing | p
Tinkelman, 1996 | Cetirizine 10 mg^a^ | 62/62 | 2 | -0.7 | NS | -0.5 | NS
| Chlorpheniramine 2 mg | 63/63 | 2 | -0.8 | NS | -0.5 | NS

N/n = Number of patients randomized to comparator groups of interest/number of patients analyzed; NS= non-significant.

a Dose was determined based on body weight.

Appendix Table C89 Eye symptom outcomes–oral selective antihistamine versus oral nonselective antihistamine in children

Author, Year | Drug, Dose/Day | N/n | Time, weeks | Itching eyes | p | Watering eyes | p
Tinkelman, 1996 | Cetirizine 10 mg | 62/62 | 2 | -0.6 | NS | -0.2 | NS
| Chlorpheniramine 2 mg | 63/63 | 2 | -0.7 | | -0.3

N/n = number of patients randomized to comparator groups of interest/number of patients analyzed; NS = non-significant.