# Excluded Studies

Appendix Table B1 Key to study exclusion coding system

Code | Definition
FLA | Foreign language article
IRD | Incomplete data reported
MAC | Mixed adult and children populations
MSP | Mixed SAR and PAR populations
NDE | Not relevant design
NRC | Not relevant comparator
NRD | Not relevant disease
NRO | Not relevant outcome
UTO | Unable to obtain

Aaronson, Ehrlich NJ, Frankel DB, Gutman AA, Aaronson DW. Effective oral nasal decongestion. A double-blind, crossover analysis. Annals of Allergy. 1968;26(3):145-50. NRC. [pmid: 4171292].
Adkins, Angello JT, Cetnarowski WE, Druce HM, Lampl KL, Vandewalker ML, D. P. H. S. Group. Diphenydramine shows superior efficacy to loratadine in sar. Annals of Allergy, Asthma & Immunology. 2001;86:136. NDE.
Anderson, Marshall NE, Clark MC. A double-blind controlled trial of disodium cromoglycate in seasonal allergic rhinitis. The Practitioner. 1972;208(247):676-9. NDE. [pmid: 4627165].
Anon. Azelastin nasal spray more effective than oral desloratadine. Pediatriya. 2006;46(3):65-6. FLA.
Aschan. Decongestion of nasal mucous membranes by oral medication in acute rhinitis. A rhinomanometric study to demonstrate synergism between antihistamines and adrenergic substance. Acta Otolaryngol. 1974;77(6):433-8. NRC. [pmid: 4600134].
Ashe. Oral medications in nasal decongestion. A study among industrial workers. IMS, Industrial medicine and surgery. 1968;37(3):212-4. NRC.
Axelsson, Lindholm B. The effect of triamcinolone acetonide on allergic and vasomotor rhinitis. Acta Oto-Laryngologica. 1972;73(1):64-7. NDE. [pmid: 4551429].
Bachert, Maurer M. Safety and efficacy of desloratadine in subjects with seasonal allergic rhinitis or chronic urticaria: Results of four postmarketing surveillance studies. Clinical Drug Investigation. 2010;30(2):109-122. NRC. [pmid: 20067329].
Badorrek, Dick M, Schauerte A, Hecker H, Murdoch R, Luettig B, Hohlfeld JM, Krug N. A combination of cetirizine and pseudoephedrine has therapeutic benefits when compared to single drug treatment in allergic rhinitis. Int J Clin Pharmacol Ther. 2009;47(2):71-7. NDE. [pmid: 19203562].
Bender, Milgrom H. Comparison of the effects of fluticasone propionate aqueous nasal spray and loratadine on daytime alertness and performance in children with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2004;92(3):344-9. MAC. [pmid: 15049399].
Bender, McCormick DR, Milgrom H. Children's school performance is not impaired by short-term administration of diphenhydramine or loratadine. J Pediatr. 2001;138(5):656-60. NDE. [pmid: 11343039].
Bender, Berning S, Dudden R, Milgrom H, Tran ZV. Sedation and performance impairment of diphenhydramine and second-generation antihistamines: A meta-analysis. Journal of Allergy and Clinical Immunology. 2003;111(4):770-776. NRD. [pmid: 12704356].
Bentley, Walker S, Hanotte F, De Vos C, Durham SR. A comparison of the effects of oral cetirizine and inhaled beclomethasone on early and late asthmatic responses to allergen and the associated increase in airways hyperresponsiveness. Clin Exp Allergy. 1996;26(8):909-17. NDE. [pmid: 8877156].
Berger, Fineman SM, Lieberman P, Miles RM. Double-blind trials of azelastine nasal spray monotherapy versus combination therapy with loratadine tablets and beclomethasone nasal spray in patients with seasonal allergic rhinitis. Rhinitis Study Groups. Ann Allergy Asthma Immunol. 1999;82(6):535-41. NRC. [pmid: 10400480].
Berger. Desloratadine reduces seasonal allergic rhinitis symptoms in patients with seasonal allergenic rhinitis and asthma. Journal of Allergy and Clinical Immunology. 2001;107(2):S162. NDE.
Bhatia, Baroody FM, deTineo M, Naclerio RM. Increased nasal airflow with budesonide compared with desloratadine during the allergy season. Arch Otolaryngol Head Neck Surg. 2005;131(3):223-8. NDE. [pmid: 15781762].
Bousquet, Bindslev-Jensen C, Canonica GW, Fokkens W, Kim H, Kowalski M, Magnan A, Mullol J, van Cauwenberge P. The ARIA/EAACI criteria for antihistamines: an assessment of the efficacy, safety and pharmacology of desloratadine. Allergy. Suppl 77. 2004;59:4-16. NDE. [pmid: 15236647].
Bozkurt, Karakaya G, Kalyoncu AF. Seasonal rhinitis, clinical characteristics and risk factors for asthma. International Archives of Allergy and Immunology. 2005;138(1):73-79. NRC. [pmid: 16103690].
Britton, Empey DW, John GC, McDonnell KA, Hughes DT. Histamine challenge and anterior nasal rhinometry: their use in the assessment of pseudoephedrine and triprolidine as nasal decongestants in subjects with hayfever. Br J Clin Pharmacol. 1978;6(1):51-8. NDE. [pmid: 78718].
Bronsky, Tarpay M, Tinkelman DA, Bush JK. A comparison of two dosing regimens of beclomethasone dipropionate aqueous nasal spray and flunisolide nasal spray in the treatment of acute seasonal rhinitis. Immunology and Allergy Practice. 1987;9(5):165-170. NRC.
Brooks. Spectrum of seasonal allergic rhinitis symptom relief with topical corticoid and oral antihistamine given singly or in combination. American Journal of Rhinology. 1996;10(3):193-199. MAC.
Brown, Engler C, English JR. A comparative trial of flunisolide and sodium cromoglycate nasal sprays in the treatment of seasonal allergic rhinitis. Clinical Allergy. 1981;11(2):169-73. MAC. [pmid: 6786796].
Brozek, Bousquet J, Baena-Cagnani CE, Bonini S, Canonica GW, Casale TB, Van Wijk RG, Ohta K, Zuberbier T, Schunemann HJ. Allergic Rhinitis and its Impact on Asthma (ARIA) guidelines: 2010 Revision. Journal of Allergy and Clinical Immunology. 2010;126(3):466-476. NDE. [pmid: 20816182].
Bruno, Errigo E, Del Giacco GS. A multicentre study to evaluate the efficacy and safety of BW825C (Acrivastine) in the treatment of seasonal allergic rhinitis. European Review for Medical and Pharmacological Sciences. 1986;8(3):305-317. NRC.
Calderon Moises, Rodriguez del Rio P, Demoly P. Topical nasal corticosteroids versus oral antihistamines for allergic rhinitis. Calderon Moises A, Rodriguez del Rio Pablo, Demoly Pascal Topical nasal corticosteroids versus oral antihistamines for allergic rhinitis. Cochrane Database of Systematic Reviews: Protocols. John Wiley & Sons, Ltd. Chichester, UK. [doi: 10.1002/14651858]. 2010;(1):CD008232. 2010 (1). NDE.
Can, Tanac R, Demir E, Gulen F, Veral A. Is the usage of intranasal glucocorticosteroids alone in allergic rhinitis sufficient?. Allergy Asthma Proc. 2006;27(3):248-53. MAC. [pmid: 16913269].
Carroll. Effective use of corticosteroids in allergic rhinitis. Current Therapeutics. 1984;25(11):55-60. NDE.
Charpin, Vervloet D. Treating seasonal rhinitis: Antihistamines or intranasal corticosteroids?. European Respiratory Review. 1994;4(20):256-259. NDE.
Cierpiol-Tracz, Kawalski H, Szpyrka G, Mos M, Kopacz M. Comparative study of the application of sympathomimetic generally and locally as combined with loratadine in the initial therapy of allergic rhinitis in older children. New Medicine. 1999;3:16-17. NRC.
Cingi, Gunhan K, Gage-White L, Unlu H. Efficacy of leukotriene antagonists as concomitant therapy in allergic rhinitis. Laryngoscope. 2010;120(9):1718-23. NRC. [pmid: 20717951].
Coffman. A controlled trial of disodium cromoglycate in seasonal allergic rhinitis. Br J Clin Pract. 1971;25(9):403-6. NDE. [pmid: 4398799].
Condemi, Lim J. Triamcinolone acetonide aqueous nasal spray compared with loratadine in seasonal allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1997;78:127. Level 4, NDE.
Connell, Williams BO, Allen S, Cato A, Perkins JG. A double-blind controlled evaluation of Actifed and its individual constituents in allergic rhinitis. J Int Med Res. 1982;10(5):341-7. NRC. [pmid: 6128282].
Connell. Effectiveness of topical nasal decongestants. Ann Allergy. 1969;27(11):541-6. NRC. [pmid: 4195892].
Cordray, Harjo JB, Miner L. Comparison of intranasal hypertonic dead sea saline spray and intranasal aqueous triamcinolone spray in seasonal allergic rhinitis. Ear Nose Throat J. 2005;84(7):426-30. NDE. [pmid: 16813032].
Corrado, Ollier S, Phillips MJ. Histamine and allergen induced changes in nasal airways resistance measured by anterior rhinomanometry: Reproducibility of the technique and the effect of topically administered antihistaminic and anti-allergic drugs. British Journal of Clinical Pharmacology. 1987;24(3):283-292. NDE. [pmid: 3117084].
Corren. Desloratadine reduces the use of inhaled Beta²-agonists and improves asthma symptoms in patients with seasonal allergic rhinitis ans asthma. Journal of Allergy and Clinical Immunology. 2001;107(2):S163. NDE.
Costa, Amouyal M, Lambert P, Ryan D, Schunemann HJ, Daures JP, Bousquet J, Bousquet PJ. How representative are clinical study patients with allergic rhinitis in primary care?. J Allergy Clin Immunol. 2011;127(4):920-6 e1. NRC. [pmid: 21269670].
Crim, Pierre LN, Daley-Yates PT. A review of the pharmacology and pharmacokinetics of inhaled fluticasone propionate and mometasone furoate. Clin Ther. 2001;23(9):1339-54. NDE. [pmid: 11589253].
Dahl, Lange B, Holtappels G, Lukat KF, Bachert C. Effects of cetirizine and fluticasone propionate nasal spray on symptoms and inflammatory mediators of seasonal allergic rhinitis. Allergologie. 2004;27(1):16-25. FLA.
Dahl, Baker RC, Pauwel R. Seasonal rhinitis and asthma. Effects of topical nasal and/or orally inhaled Fluticasone Propionate, the SPIRA study (FNM40001). Journal of Allergy and Clinical Immunology. 2001;107(2):S154. NDE.
D'Ambrosio, Gangemi S, Merendino RA, Arena A, Ricciardi L, Bagnato GF. Comparative study between fluticasone propionate and cetirizine in the treatment of allergic rhinitis. Allergol Immunopathol (Madr). 1998;26(6):277-82. [pmid: 9934406].
Das. Treatment of allergic rhinitis in children: What's new?. Journal of Paediatrics and Child Health. 2012;48(4):366. NDE. [pmid: 22486796].
Day, Briscoe M, Rafeiro E, Kramer B. Onset of action and symptom relief with cetirizine, loratadine, or placebo in an environmental exposure unit eeu in ragweed-sensitive subjects with seasonal allergic rhinitis sar. Annals of Allergy, Asthma & Immunology. 2000;84:125. NDE.
Day, Briscoe MP, Ratz JD. Efficacy of levocetirizine compared with montelukast in subjects with ragweed-induced seasonal allergic rhinitis in the Environmental Exposure Unit. Allergy Asthma Proc. 2008;29(3):304-12. NDE. [pmid: 18387222].
Day, Briscoe MP, Ratz JD, Danzig M, Yao R. Efficacy of loratadine-montelukast on nasal congestion in patients with seasonal allergic rhinitis in an environmental exposure unit. Ann Allergy Asthma Immunol. 2009;102(4):328-38. NDE. [pmid: 19441605].
Deering, Derbyshire MJ, Johnson PA. An antihistamine-sympathomimetic combination in the treatment of hayfever. Practitioner. 1981;225(1356):929-931. NDE. [pmid: 7029507].
Delucchi, Valenzuela J, Cofre O, Martinez A. Double-blind comparative trial of ipratropium bromide in chronic vasomotor and allergic rhinitis in children. Revista de Otorrinolaringologia y Cirurgia de Cabeza y Cuello. 1984;44(3):85-88. FLA.
Diamond, Gerson K, Cato A, Peace K, Perkins JG. An evaluation of triprolidine and pseudoephedrine in the treatment of allergic rhinitis. Ann Allergy. 1981;47(2):87-91. NRC. [pmid: 7258744].
Dockhorn, Williams BO, Sanders RL. Efficacy of acrivastine with pseudoephedrine in treatment of allergic rhinitis due to ragweed. Ann Allergy Asthma Immunol. 1996;76(2):204-8. NRC. [pmid: 8595542].
Dockhorn, Meltzer E, Paull B, van As A, Weakley S, Woehler T, Rogenes P. Fluticasone propionate aqueous nasal spray given once a day safely controls the symptoms of seasonal allergic rhinitis. Annals of Allergy. 1990;64:77. NDE.
Dolovich, Anderson M, Chodirker W, Drouin M, Hargreave FE, Hebert J, Knight A, O'Conner M, Small P, Yang W. Fluticasone propionate: a large multicentre trial. Respiratory Medicine. Respiratory Medicine. Suppl A. 1990;84:31-2. NDE. [pmid: 2287794].
Dorow, Aurich R, Petzold U. Efficacy and tolerability of azelastine nasal spray in patients with allergic rhinitis compared to placebo and budesonide. Arzneimittelforschung. 1993;43(8):909-12. NDE. [pmid: 8105785].
Dorow, Thalhofer S, Aurich R, Petzold U. Azelastine nasal spray in the treatment of patients suffering from allergic rhinitis - comparison versus placebo and budesonide. Atemwegs- und Lungenkrankheiten. 1992;18(11):501. NDE.
Drouin, Yang WH, Horak F, Van de Heyning PH, Kunkel GH, Backhouse CI, Danzig MR. Adding loratadine to topical nasal steroid therapy improves moderately severe seasonal allergic rhinoconjunctivitis. Advances in Therapy. 1995;12(6):340-349. NDE.
Druce, Thoden WR, Mure P, Furey SA, Lockhart EA, Xie T, Galant S, Prenner BM, Weinstein S, Ziering R, Brandon ML. Brompheniramine, loratadine, and placebo in allergic rhinitis: a placebo-controlled comparative clinical trial. J Clin Pharmacol. 1998;38(4):382-9. NRD. [pmid: 9590467].
D'Souza, Emanuel MB, Gregg J, Charlton J, Goldschmidt J. A method for evaluating therapy for hay fever. A comparison of four treatments. Clin Allergy. 1983;13(4):329-35. NRC. [pmid: 6411382].
Empey, Bye C, Hodder M, Hughes DT. A Double-blind crossover trial of pseudoephedrine and triprolidine, alone and in combination, for the treatment of allergenic rhinitis. Ann Allergy. 1975;34(1):41-6. NRC. [pmid: 1098524].
Empey, Frosolono MF, Hughes DT, Perkins JG. Comparison of pseudoephedrine and triprolidine, alone and in combination in preventing nasal congestion in subjects with allergic rhinitis using nasal histamine challenge. Br J Clin Pharmacol. 1984;18(1):86-9. NDE. [pmid: 6204666].
Engstrom, Oberger E, Blyckert A, Kraepelien S. Disodium cromoglycate in the treatment of seasonal allergic rhinoconjunctivitis in children. Annals of Allergy. 1971;29(10):505-9. MAC. [pmid: 4999756].
Engstrom. The effect of disodium cromoglycate on nasal provocation tests in children with seasonal allergic rhinitis. Acta Allergol. 1971;26(2):101-5. NDE. [pmid: 4999239].
Fairchild, Durden E, Cao Z, Smale P. Outcomes and cost comparison of three therapeutic approaches to allergic rhinitis. American Journal of Rhinology & Allergy. 2011;25(4):257-62. NRD. [pmid: 21639996].
Fang, Perng DW, Lee JY, Lin DY, Huangs CY. An open-label, multicentre study of levocetirizine for the treatment of allergic rhinitis and urticaria in Taiwanese patients. Chin J Physiol. 2010;53(4):199-207. NRC. [pmid: 21793329].
Ferrer, Morais-Almeida M, Guizova M, Khanferyan R. Evaluation of treatment satisfaction in children with allergic disease treated with an antihistamine: an international, non-interventional, retrospective study. Clin Drug Investig. 2010;30(1):15-34. NRD.
Fisher. Comparison of budesonide and disodium cromoglycate for the treatment of seasonal allergic rhinitis in children. Ann Allergy. 1994;73(6):515-20. MAC. [pmid: 7998667].
Frolund. Efficacy of an oral antihistamine, loratadine, as compared with a nasal steroid spray, beclomethasone dipropionate, in seasonal allergic rhinitis. Clin Otolaryngol Allied Sci. 1991;16(6):527-31. NRO. [pmid: 1685945].
Fu, Dai Q, Xiong YQ. Clinical study of treatment of allergic rhinitis with triamcinolone acetonide nasal spray. Chinese Journal of Clinical Pharmacology. 2001;17(5):341-3. FLA.
Garavello, Di Berardino F, Romagnoli M, Sambataro G, Gaini RM. Nasal rinsing with hypertonic solution: an adjunctive treatment for pediatric seasonal allergic rhinoconjunctivitis. Int Arch Allergy Immunol. 2005;137(4):310-4. NRC. [pmid: 15970639].
Geller, Rubin JM, Cannon SJ, Anand S. Clinical trial of a new long-acting combination antihistamine-decongestant tablet in the treatment of seasonal allergic rhinitis. Immunology and Allergy Practice. 1983;5(5):157-161. UTO.
Georgitis, Meltzer EO, Kaliner M, Weiler J, Berkowitz R. Onset-of-action for antihistamine and decongestant combinations during an outdoor challenge. Ann Allergy Asthma Immunol. 2000;84(4):451-9. NDE. [pmid: 10795655].
Gomez, Gomez G. Hay fever and allergy in general practice: two antihistamine drugs compared. Br J Clin Pract. 1967;21(8):401-3. NRC. [pmid: 4383828].
Gordon, Caplinger KJ, Meade JH, Thompson C. Correlation of type specific fluorescent antibodies to ragweed with symptomatology: double-blind study. Annals of Allergy. 1972;30(9):507-17. MAC. [pmid: 4560390].
Gorur, Ozcan C, Murat U, Umit-Talas D, Kilinc S. Evaluation of efficacy of nasal sprays containing mometasone furoate and azelastine hydrochloride in the management of allergic rhinitis. Turkish Archives of Otolaryngology. 2002;40(1):13-16. FLA.
Grainger, Drake-Lee A. Montelukast in allergic rhinitis: a systematic review and meta-analysis. Clin Otolaryngol. 2006;31(5):360-7. NDE. [pmid: 17014443].
Green. Double-blind study of nasal decongestion with oxymetazoline and phenylephrine in asthmatic children with rhinitis. Review of allergy. 1966;20(9):863-8. NRC. [pmid: 4162601].
Haahtela. Comparisons among HC 20-211 (Ketotifen), clemastine, DSCG and beclomethasone dipropionate in nasal challenge. Annals of Allergy. 1978;41(6):345-7. NDE. [pmid: 103469].
Hayashi, Miyata A, Yamada T. The impact of commonly prescribed drugs on male fertility. Human Fertility. 2008;11(3):191-196. NRC. [pmid: 18608524].
Hernandez, Mitchell AA, Werler MM. Decongestant use during pregnancy and its association with preterm delivery. Birth Defects Res A Clin Mol Teratol. 2010;88(9):715-21. NRC. [pmid: 20672347].
Hetherington. Hay fever in a student population. A trial of disodium cromoglycate. Med J Aust. 1973;1(10):493-4. NDE. [pmid: 4633689].
Hill 3rd, Krouse JH. The effects of montelukast on intradermal wheal and flare. Otolaryngol Head Neck Surg. 2003;129(3):199-203. NDE. [pmid: 12958567].
Holopainen, Salo OP, Backman A. Experiences with disodium cromoglycate in treatment of seasonal and perennial allergic rhinitis. Rhinology. 1972;10(3):119-126. NDE.
Hong, Bielory B, Rosenberg JL, Bielory L. Efficacy of intranasal corticosteroids for the ocular symptoms of allergic rhinitis: A systematic review. Allergy Asthma Proc. 2011;32(1):22-35. NDE. [pmid: 21262095].
Horak, Zieglmayer UP, Zieglmayer R, Kavina A, Marschall K, Munzel U, Petzold U. Azelastine nasal spray and desloratadine tablets in pollen-induced seasonal allergic rhinitis: a pharmacodynamic study of onset of action and efficacy. Curr Med Res Opin. 2006;22(1):151-7. NDE. [pmid: 16393441].
Howard, Bowers BW, Cook CK, Westlund R, Rickard K. Intranasal fluticasone, loratadine tablets, and their use in combination: An evaluation of economic and humanistic outcomes. Drug Benefit Trends. 2001;13(10):45-46. 48. 51. 52. NDE.
Howland, Ratner PH, Jacobs RL, Reed KD, Prillaman BA, Crim C, Cooke CK. Fluticasone propionate aqueous nasal spray relieves sinus pain and pressure in patients with allergic rhinitis. Journal of Allergy and Clinical Immunology. 2001;107(2):S154. NDE.
Huang, Giannoni C. The risk of adenoid hypertrophy in children with allergic rhinitis. Annals of Allergy, Asthma, & Immunology. 2001;87(4):350-5. NDE.
Hurwitz. Treatment of allergic rhinitis with antihistamines and decongestants and their effects on the lower airway. Pediatric Annals. 2000;29(7):411-420. NDE. [pmid: 10911630].
Illum, Meistrup-Larsen U, Moesner J, Olesen K, Olsen SZ. Disodium cromoglycate (Lomudal) in the treatment of hay fever. Acta Allergol. 1973;28(5):416-24. NDE. [pmid: 4150611].
Irander, Odkvist LM, Ohlander B. Treatment of hay fever with loratadine--a new non-sedating antihistamine. Allergy. 1990;45(2):86-91. NRC. [pmid: 2138436].
Izumi, Mizuguchi H, Umehara H, Ogino S, Fukui H. Analysis of disease-dependent sedative profiles of H1- antihistamines by large-scale surveillance using the visual analog scale. Methods and Findings in Experimental and Clinical Pharmacology. 2008;30(3):225-230. MAC. [pmid: 18597008].
Izumi, Mizuguchi H, Umehara H, Ogino S, Fukui H. Evaluation of efficacy and sedative profiles of H(1) antihistamines by large-scale surveillance using the visual analogue scale (VAS). Allergol Int. 2008;57(3):257-63. NDE. [pmid: 18566547].
Juniper, Guyatt GH, Dolovich J. Assessment of quality of life in adolescents with allergic rhinoconjunctivitis: development and testing of a questionnaire for clinical trials. The Journal of allergy and clinical immunology. 1994;93(2):413-23. NDE. [pmid: 8120268].
Kalpaklioglu, Kavut AB. Comparison of azelastine versus triamcinolone nasal spray in allergic and nonallergic rhinitis. Am J Rhinol Allergy. 2010;24(1):29-33. MSP. [pmid: 20109317].
Kapstad, Warland A. Therapeutic effectiveness of an oral anti-histamine combination (dexbrompheniramine maleate/d-isoephedrine sulphate) in the treatment of patients with allergic rhinitis. Acta Allergol. 1976;31(3):223-6. NDE. [pmid: 782134].
Katelaris, Lai CKW, Rhee CS, Lee SH, De Yun W, Lim-Varona L, Quang VT, Hwang J, Singh H, Kim J, Boyle JM, Dhong HJ, Narayanan P, Vicente G, Blaiss M, Sacks R. Nasal allergies in the Asian - Pacific population: Results from the Allergies in Asia-Pacific Survey. American Journal of Rhinology and Allergy. 2011;25(5 SUPPL. 1):S3-S15. NDE. [pmid: 22185687].
Keith, Koch C, Djandji M, Bouchard J, Psaradellis E, Sampalis JS, Schellenberg RR, McIvor RA. Montelukast as add-on therapy with inhaled corticosteroids alone or inhaled corticosteroids and long-acting beta-2-agonists in the management of patients diagnosed with asthma and concurrent allergic rhinitis (the RADAR trial). Can Respir J. Suppl A. 2009;16:17A-31A. NRC.
Kellerman, et al. Superiority of beclomethasone over cromolyn in the self-treatment of seasonal allergic rhinitis. Pharmacotherapy. 1998;18:1165. NDE.
Keskin, Alyamac E, Tuncer A, Dogan C, Adalioglu G, Sekerel BE. Do the leukotriene receptor antagonists work in children with grass pollen-induced allergic rhinitis?. Pediatr Allergy Immunol. 2006;17(4):259-68. NRC. [pmid: 16771779].
Koberlein, Vent J, Mosges R, Wieland R. Effectiveness of guidelines in treatment of allergic rhinitis: An analysis of individual patient data. Journal of Public Health. 2011;19(6):563-568. NDE.
Kostadinova, Badzakova G, Stevic V. Budesonide and Loratadine in the treatment of allergic rhinitis in children abstract. The European respiratory journal. 2003;22(Suppl 45):134s. NDE.
Kotaniemi-Syrjanen, Reijonen TM, Korhonen K, Korppi M. Sodium cromoglycate therapy in wheezing infants: Preliminary evidence of beneficial outcome at early school age. Pediatrics International. 2005;47(6):627-634. NRD. [pmid: 16354214].
Kubo, Senda M, Ohsumi Y, Sakamoto S, Matsumoto K, Tashiro M, Okamura N, Yanai K. Brain histamine H1 receptor occupancy of loratadine measured by positron emission topography: comparison of H1 receptor occupancy and proportional impairment ratio. Human Psychopharmacology. 2011;26(2):133-9. NRD. [pmid: 21433074].
Kupczyk, Kuprys I, Gorski P, Kuna P. The effect of montelukast (10mg daily) and loratadine (10mg daily) on wheal, flare and itching reactions in skin prick tests. Pulm Pharmacol Ther. 2007;20(1):85-9. NDE. [pmid: 16516511].
Kurowski, Kuna P, Gorski P. Montelukast plus cetirizine in the prophylactic treatment of seasonal allergic rhinitis: influence on clinical symptoms and nasal allergic inflammation. Allergy. 2004;59(3):280-8. IRD. [pmid: 14982509].
LaForce, Corren J, Wheeler WJ, Berger WE. Efficacy of azelastine nasal spray in seasonal allergic rhinitis patients who remain symptomatic after treatment with fexofenadine. Ann Allergy Asthma Immunol. 2004;93(2):154-9. NRC. [pmid: 15328675].
LaForce, Dockhorn RJ, Prenner BM, Chu TJ, Kraemer MJ, Widlitz MD, D'Eletto TA, Freitag JJ. Safety and efficacy of azelastine nasal spray (Astelin NS) for seasonal allergic rhinitis: a 4-week comparative multicenter trial. Ann Allergy Asthma Immunol. 1996;76(2):181-8. NRC. [pmid: 8595539].
LaForce, Carr W, Tilles SA, Chipps BE, Storms W, Meltzer EO, Edwards M. Evaluation of olopatadine hydrochloride nasal spray, 0.6%, used in combination with an intranasal corticosteroid in seasonal allergic rhinitis. Allergy Asthma Proc. 2010;31(2):132-40. NRC. [pmid: 20302683].
Lal. Effect of a few histamine1-antagonists on blood glucose in patients of allergic rhinitis. Indian Journal of Otolaryngology and Head and Neck Surgery. 2000;52(2):193-195. NRD. [pmid: 23119674].
Lanier, Abelson MB, Berger WE, Granet DB, D'Arienzo PA, Spangler DL, Kagi MK. Comparison of the efficacy of combined fluticasone propionate and olopatadine versus combined fluticasone propionate and fexofenadine for the treatment of allergic rhinoconjunctivitis induced by conjunctival allergen challenge. Clin Ther. 2002;24(7):1161-74. NDE. [pmid: 12182260].
Layton, Wilton L, Boshier A, Cornelius V, Harris S, Shakir SA. Comparison of the risk of drowsiness and sedation between levocetirizine and desloratadine: a prescription-event monitoring study in England. Drug Saf. 2006;29(10):897-909. MSP. [pmid: 16970513].
Lee, Pickard AS. Meta-analysis of azelastine nasal spray for the treatment of allergic rhinitis. Pharmacotherapy. 2007;27(6):852-9. NDE. [pmid: 17542768].
Lee, Haggart K, Currie GP, Anderson SD, Lipworth BJ. The effects of histamine and leukotriene receptor antagonism on nasal mannitol challenge in allergic rhinitis. Br J Clin Pharmacol. 2003;55(6):639-42. NDE. [pmid: 12814463].
Leonhardt, Gale NM, Gibbs TG. Placebo-controlled, randomized evaluation of acrivastine in seasonal allergic rhinitis. Acta Therapeutica. 1988;14(3):241-248. NDE.
Lipworth, Wison A. Effects of intranasal administration with triamcinolone acetonide Triamcinolone acetonide A, mometasone furoate Mometasone furoate and budesonide Budesonide on 24 hour adrenocortical activity in allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1999;82:75. NDE.
Lou, Wang DH, Hu XY, Huang XQ, He ZY, Zheng WS. Efficacy and safety of cetirizine-pseudoephedrine sustained-release tablets in the treatment of seasonal and perennial allergic rhinitis. Chinese Journal of New Drugs. 2009;18(1):43-6. 52. FLA.
Luo, Cappelleri JC, Frush K. A systematic review on the application of pharmacoepidemiology in assessing prescription drug-related adverse events in pediatrics. Current Medical Research and Opinion. 2007;23(5):1015-1024. NRC. [pmid: 17526119].
Magen, Yosefy C, Viskoper RJ, Mishal J. Treatment of allergic rhinitis can improve blood pressure control. J Hum Hypertens. 2006;20(11):888-93. NDE. [pmid: 16967045].
Mahadevia, Shah S, Leibman C, Kleinman L, O'Dowd L. Patient preferences for sensory attributes of intranasal corticosteroids and willingness to adhere to prescribed therapy for allergic rhinitis: a conjoint analysis. Annals of Allergy, Asthma, & Immunology. 2004;93(4):345-50. NRC.
Martin, Cook CK, van Bavel JH, Reed KD, Hampel FC, Prillaman BA, Crim C. Fluticasone propionate aqueous nasal spray for the treatment on finus pain and pressure associated with nasal congestion in patients with allergic rhinitis. Annals of Allergy, Asthma & Immunology. 2001;86:114. NDE.
Martinati, Sette L, Chiocca E, Zaninotto M, Plebani M, Boner AL. Effect of beclomethasone dipropionate nasal aerosol on serum markers of bone metabolism in children with seasonal allergic rhinitis. Clin Exp Allergy. 1993;23(12):986-91. MAC. [pmid: 10779290].
Mascia. Objective assessment of nasal airway in children: an evaluation of decongestant therapy. Annals of Allergy. 1968;26(9):470-5. NDE. [pmid: 4176197].
Masuyama, Till SJ, Jacobson MR, Kamil A, Cameron L, Juliusson S, Lowenhagen O, Kay AB, Hamid QA, Durham SR. Topical corticosteroids inhibit nasal eosinophelia and IL-5 mRNA expression in seasonal allergic rhinitis induced by natural grass pollen exposure. Rhinology. 1999;37(SUPPL. 15):10-10. NDE.
Matsunaga, Yanagisawa S, Ichikawa T, Akamatsu K, Koarai A, Hirano T, Sugiura H, Minakata Y, Ichinose M. Molecular mechanism of the additive effects of leukotriene modifier in asthmatic patients receiving steroid therapy. Allergol Int. 2009;58(1):89-96. NRC. [pmid: 19153534].
Mayer, Savitt AE. Allergic rhinitis and air pollution: a double-blind crossover analysis. Eye, ear, nose & throat monthly. 1972;51(1). 33-4 passim. NRC.
Meltzer, Philip G, Weinstein SF, LaForce CF, Malice MP, Dass SB, Santanello NC, Reiss TF. Montelukast effectively treats the nighttime impact of seasonal allergic rhinitis. Am J Rhinol. 2005;19(6):591-8. NDE. [pmid: 16402647].
Meltzer, Weiler JM, Dockhorn RJ, Widlitz MD, Freitag JJ. Azelastine nasal spray in the management of seasonal allergic rhinitis. Ann Allergy. 1994;72(4):354-9. NRC. [pmid: 7908778].
Meran, Morse J, Gibbs TG. A cross-over comparison of acrivastine, pseudoephedrine and their combination in seasonal allergic rhinitis. Rhinology. 1990;28(1):33-40. NDE. [pmid: 1970907].
Mercke, Wihl JA. Clinical evaluation of an oral combined antihistaminic sympathomimetic preparation. Acta Allergol. 1973;28(2):108-17. NRC. [pmid: 4149085].
Miller. A double-blind study of d-isoephedrine combined with chlorpheniramine in symptomatic relief of hay fever. Medical times. 1967;95(3):306-9. NDE. [pmid: 5341588].
Min, Zheng Y, Liu SX, Liang CY, Hu CH. Randomized controlled trial of compound loratadine capsule in the treatment of allergic rhinitis. Chinese Journal of Evidence-Based Medicine. 2004;4(10):673-6. FLA.
Min. A multi-center randomized controlled single-blinded trial of compound loratadine capsule and loratadine psudoephadrine tablet for allergic rhinitis dissertation. China National Knowledge Infrastructure (CNKI). 2004. FLA.
Mitchell, Davis N, Koenig W, Blank P. Emulsion therapy: a three-year study with ragweed pollinosis. Annals of Allergy. 1971;29(11):564-72. NRC. [pmid: 4941343].
Modgill, Badyal DK, Verghese A. Efficacy and safety of montelukast add-on therapy in allergic rhinitis. Methods Find Exp Clin Pharmacol. 2010;32(9):669-74. NRD. [pmid: 21225018].
Moinuddin, deTineo M, Maleckar B, Naclerio RM, Baroody FM. Comparison of the combinations of fexofenadine-pseudoephedrine and loratadine-montelukast in the treatment of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2004;92(1):73-9. NRC. [pmid: 14756468].
Morrow-Brown, Jackson FA, Pover GM. A comparison of beclomethasone dipropionate aqueous nasal spray and sodium cromoglycate nasal spray in the management of seasonal allergic rhinitis. Allergologia et Immunopathologia. 1984;12(5):355-361. MAC. [pmid: 6441477].
Mosges, Konig V, Koberlein J. The effectiveness of levocetirizine in comparison with loratadine in treatment of allergic rhinitis -a meta-analysis. Allergology International. 2011;60(4):541-6. NRC. [pmid: 21918368].
Moss, Busse WW, Tinkelman D, Condemi J, Metzger WJ, Nickelsen JA, Barrick R, Fink JN, James L. Antihistamine-sparing effects of flunisolide in the treatment of allergic rhinitis. Current Therapeutic Research - Clinical and Experimental. 1990;48(5):866-873. NDE.
Mucha, deTineo M, Naclerio RM, Baroody FM. Comparison of montelukast and pseudoephedrine in the treatment of allergic rhinitis. Arch Otolaryngol Head Neck Surg. 2006;132(2):164-72. NRC. [pmid: 16490874].
Munch, Soborg M, Norreslet TT, Mygind N. A comparative study of dexchlorpheniramine maleate sustained release tablets and budesonide nasal spray in seasonal allergic rhinitis. Allergy. 1983;38(7):517-24. NRC. [pmid: 6139040].
Murray, Nathan R, Bronsky E, Olufade AO, Chapman D, Kramer B. Cetirizine in the management of seasonal allergic rhinitis: impact on patient health-related quality of life hrql, work productivity and activity impairment wpai. Annals of Allergy, Asthma & Immunology. 2000;84:125. NDE.
Mygind, Hansen I, Jorgensen MB. Disodium cromoglycate nasal spray in adult patients with perennial rhinitis. Acta Allergol. 1972;27(5):372-80. NRD. [pmid: 4633098].
Mygind. Topical steroid treatment for allergic rhinitis and allied conditions. Clinical Otolaryngology and Allied Sciences. 1982;7(5):343-352. NDE. [pmid: 6756710].
Nasser, Aljufairi H, McKerrow WS, Fedorowicz Z. Antihistamines as an adjunct to topical nasal steroids for intermittent and persistent allergic rhinitis in children. Cochrane Database of Systematic Reviews. 2008;(1):CD006989. NRD.
Nasser, Fedorowicz Z, Aljufairi H, McKerrow W. Antihistamines used in addition to topical nasal steroids for intermittent and persistent allergic rhinitis in children. Cochrane Database Syst Rev. 2010;(7):CD006989. NDE. [pmid: 20614452].
Nathan. The pathophysiology, clinical impact, and management of nasal congestion in allergic rhinitis. Clin Ther. 2008;30(4):573-86. NDE. [pmid: 18498908].
Navarro, Valero A, Rosales MJ, Mullol J. Clinical use of oral antihistamines and intranasal corticosteroids in patients with allergic rhinitis. J Investig Allergol Clin Immunol. 2011;21(5):363-9. NDE.
Nayak, Langdon RB. Montelukast in the treatment of allergic rhinitis: an evidence-based review. Drugs. 2007;67(6):887-901. NDE. [pmid: 17428106].
Nayak. Mometasone furoate monohydrate nasal spray for the treatment of nasal congestion in allergic rhinitis. Expert Review of Clinical Immunology. 2008;4(2):143-155. NDE. [pmid: 20477046].
Neidorff. Clinical note: double-blind comparison of the duration of effect of oxymetazoline and phenylephrine in children. Annals of Allergy. 1966;24(5):250-1. NRC. [pmid: 5327894].
Nielson, Dahl R, Mygind N, Baker RC, Howarth P, Cauwenberge PV. Comorbid seasonal allergic rhinitis and asthma need intranasal corticosteroid for the treatment of nasal disease. Results of the SPIRA study (FNM40001). Journal of Allergy and Clinical Immunology. 2001;107(2):S152. NDE.
Nsouli, Nsouli TM, Bellanti JA. Treatment of allergic rhinitis: beclomethasone dipropionate (BD) versus triamcinolone acetonide (Triamcinolone acetonide ). Annals of Allergy. 1994;72:83. NDE.
Nsouli. Combination loratadine LR and montelukast ML in the treatment of allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1999;82:90. NDE.
Nwawolo, Olusesi AD. Controlled clinical study of the efficacy of loratadine in Nigerian patients with allergic rhinitis. Niger Postgrad Med J. 2001;8(3):127-32. MSP. [pmid: 11721215].
Oei. Double-blind comparison of loratadine (SCH 29851), astemizole and placebo in hayfever with special regard to onset of action. TIJDSCHR THER GENEESM ONDERZ. 1989;14(5):133-136. FLA.
Ozgur, Arslanoglu S, Etit D, Demiray U, Onal HK. Comparison of nasal cytology and symptom scores in patients with seasonal allergic rhinitis, before and after treatment. J Laryngol Otol. 2011;125(10):1028-32. NRC. [pmid: 21791158].
Patel, Patel D. Efficacy comparison of levocetirizine vs montelukast in ragweed sensitized patients. Ann Allergy Asthma Immunol. 2008;101(3):287-94. NDE. [pmid: 18814452].
Patel, D'Andrea C, Sacks HJ. Onset of action of azelastine nasal spray compared with mometasone nasal spray and placebo in subjects with seasonal allergic rhinitis evaluated in an environmental exposure chamber. Am J Rhinol. 2007;21(4):499-503. NDE. [pmid: 17882923].
Patel, Garadi R, Brubaker M, Conroy JP, Kaji Y, Crenshaw K, Whitling A, Wall GM. Onset and duration of action of nasal sprays in seasonal allergic rhinitis patients: olopatadine hydrochloride versus mometasone furoate monohydrate. Allergy Asthma Proc. 2007;28(5):592-9. NDE. [pmid: 18034980].
Pelikan, de Vries K. Effects of some drugs applied topically to the nasal mucosa before nasal provocation tests with allergen. Acta Allergol. 1974;29(5):337-53. NDE. [pmid: 4154695].
Pfizer. A randomized, double blind, placebo controlled, four way crossover study to determine the effects of PF-03654764 +/- allegra (Fexofenadine) on symptoms of allergic rhinitis in subjects exposed to ragweed pollen in an environmental exposure unit. 2011. ClinicalTrials gov. 25 July 2011. ClinicalTrials.gov ID NCT01033396. NDE.
Philip, Hustad CM, Malice MP, Noonan G, Ezekowitz A, Reiss TF, Knorr B. Analysis of behavior-related adverse experiences in clinical trials of montelukast. Journal of Allergy and Clinical Immunology. 2009;124(4):699-706.e8. NDE. [pmid: 19815116].
Pinar, Eryigit O, Oncel S, Calli C, Yilmaz O, Yuksel H. Efficacy of nasal corticosteroids alone or combined with antihistamines or montelukast in treatment of allergic rhinitis. Auris Nasus Larynx. 2008;35(1):61-6. NDE. [pmid: 17826020].
Prenner, Anolik R, Danzig M, Yao R. Efficacy and safety of fixed-dose loratadine/montelukast in seasonal allergic rhinitis: effects on nasal congestion. Allergy Asthma Proc. 2009;30(3):263-9. NRC. [pmid: 19549427].
Prenner, Lu S, Danzig MR. Safety of fixed-dose loratadine/montelukast in subjects with allergic rhinitis. Allergy Asthma Proc. 2010;31(6):493-8. NDE. [pmid: 21708061].
Prevost, Turenne Y, Moote DW, Mazza J, Clermont A, PetitClerc C, Danzig MR. Comparative study of SCH 434 and CTM-D in the treatment of seasonal allergic rhinitis. Clin Ther. 1994;16(1):50-6. NRC. [pmid: 7911402].
Price, Kemp L, Sims E, von Ziegenweidt J, Navaratnam P, Lee AJ, Chisholm A, Hillyer EV, Gopalan G. Observational study comparing intranasal mometasone furoate with oral antihistamines for rhinitis and asthma. Prim Care Respir J. 2010;19(3):266-73. MAC. [pmid: 20571732].
Raphael, Angello JT, Wu MM, Druce HM. Efficacy of diphenhydramine vs desloratadine and placebo in patients with moderate-to-severe seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2006;96(4):606-14. NDE. [pmid: 16680933].
Reis, Reis L, Machado AN. Effect of nasal topical corticosteroid and allergen avoidance in children with allergic rhinitis and bronchial asthma. Rev Bras Alergia Imunopatol. 2008;(31 6):237-43. FLA.
Reitberg, Del Rio E, Weiss SL, Rebell G, Zaias N. Single-patient drug trial methodology for allergic rhinitis. Ann Pharmacother. 2002;36(9):1366-74. NDE. [pmid: 12196053].
Rodrigo, Yanez A. The role of antileukotriene therapy in seasonal allergic rhinitis: a systematic review of randomized trials. Ann Allergy Asthma Immunol. 2006;96(6):779-86. NDE. [pmid: 16802764].
Rogkakou, Guerra L, Massacane P, Baiardini I, Baena-Cagnani R, Zanella C, Canonica GW, Passalacqua G. Effects on symptoms and quality of life of hypertonic saline nasal spray added to antihistamine in persistent allergic rhinitis--a randomized controlled study. Eur Ann Allergy Clin Immunol. 2005;37(9):353-6. NRD. [pmid: 16453969].
Ruff, Salem A, Boutaric P, Brouet G. A two-stage clinical assessment of beclomethasone dipropionate aerosols. Postgraduate Medical Journal. Suppl 4. 1975;51:54-7. NDE. [pmid: 1105519].
Saengpanich, deTineo M, Naclerio RM, Baroody FM. Fluticasone nasal spray and the combination of loratadine and montelukast in seasonal allergic rhinitis. Arch Otolaryngol Head Neck Surg. 2003;129(5):557-62. NRC. [pmid: 12759270].
Salapatek, Lee J, Patel D, D'Angelo P, Liu J, Zimmerer RO Jr, Pipkin JD. Solubilized nasal steroid (CDX-947) when combined in the same solution nasal spray with an antihistamine (CDX-313) provides improved, fast-acting symptom relief in patients with allergic rhinitis. Allergy and Asthma Proceedings. 2011;32(3):221-229. NDE. [pmid: 21477425].
Salerno, Jackson JL, Berbano EP. Effect of oral pseudoephedrine on blood pressure and heart rate: a meta-analysis. Arch Intern Med. 2005;165(15):1686-94. NDE. [pmid: 16087815].
Sanger. The treatment of anxiety and depression in the allergic patient. Annals of Allergy. 1969;27(10):506-10. NDE. [pmid: 4918116].
Sanofi. A randomized, double blind, parallel group study for assessing the efficacy and safety of a twice-daily fexofenadine HCl 60 mg - pseudoephedrine HCl 60 mg combination or fexofenadine HCl 60 mg - pseudoephedrine HCl 120 mg combination versus allegra? 60 mg in patients with seasonal allergic rhinitis. 2011. ClinicalTrials gov. 25 July 2011. ClinicalTrials.gov ID NCT01306721. NDE.
Sarti, Gomes-Monteiro L, Magalhaes MC. The treatment of allergic rhinitis improves the recovery from asthma and upper respiratory infections. Revista Paulista de Medicina. 1995;113(5):968-72. NRD. [pmid: 8729739].
Satdhabudha, Poachanukoon O. Efficacy of buffered hypertonic saline nasal irrigation in children with symptomatic allergic rhinitis: A randomized double-blind study. International Journal of Pediatric Otorhinolaryngology. 2012;76(4):583-588. MAC. [pmid: 22326210].
Scadding, Erkan AN, Chau H, Maskell S. Audit of nasal steroid use and effectiveness in a rhinitis clinic. Expert Review of Pharmacoeconomics and Outcomes Research. 2010;10(1):87-90. NRC. [pmid: 20121566].
Schenkel, Nolop K, Mesarina Wicki B. Evaluation of mometasone furoate NasonexÃ‚™ nasal spray with the addition of loratadine vs. placebo in the treatment of seasonal allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1997;78:126. NDE.
Schmier, Leidy N, Prasad M. Health-related quality of life outcomes of desloratadine in patients with moderate-to-severe sar. Annals of Allergy, Asthma & Immunology. 2001;86:111. NDE.
Schoenwetter, Cohen R, Gilner D, LaForce C, Leonardy J, Lumry W, Ratner P, Slivers W, Winder J, Lim J, McNally C. Triamcinolone Acetonide nasal inhaler vs Loratadine tablets in patients with seasonal ragweed allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1995;74:59. NDE.
Schulz, Smith DH, Lim J. Quality of life in patients with seasonal allergic rhinitis: triamcinolone acetonide aqueous nasal spray versus loratadine. Annals of Allergy, Asthma and Immunology. 1997;78:155. NDE.
Schumock, Lee TA, Joo MJ, Valuck RJ, Stayner LT, Gibbons RD. Association between leukotriene-modifying agents and suicide: what is the evidence?. Drug Saf. 2011;34(7):533-44. MAC. [pmid: 21663330].
Sette, Martinati LC, Chiocca E, Piovesan P, Plebani M, Boner AL. Effect of beclomethasone dipropionate aerosol nasal spray on bone turnover indices in children with seasonal allergic rhinitis. ERS Annual Congress. Frienze, Italy. September 25-29th, 1993. European Respiratory Journal Supplement. 1993;6(Suppl 17):262S. NDE.
Sheikh, Singh Panesar S, Dhami S, Salvilla S. Seasonal allergic rhinitis in adolescents and adults. Clin Evid (Online). 2007;2007. UTO.
Sheikh, Singh Panesar S, Dhami S, Salvilla S. Hay fever in adolescents and adults. Clinical Evidence. 2009. NDE.
Sichletidis, Dascalopoulou E, Chloros D, Kyriazis G, Kosmidou I, Ioannou J. Seasonal allergic rhinitis, physical exercise and anti-H1 agents. Acta Therapeutica. 1993;19(4):349-355. NDE.
Simoens, Laekeman G. Pharmacotherapy of allergic rhinitis: a pharmaco-economic approach. Allergy. 2009;64(1):85-95. NDE. [pmid: 19076532].
Singh-Franco, Ghin HL, Robles GI, Borja-Hart N, Perez A. Levocetirizine for the treatment of allergic rhinitis and chronic idiopathic urticaria in adults and children. Clin Ther. 2009;31(8):1664-87. NDE. [pmid: 19808127].
Smith, Mills P. Disodium cromoglycate in pollen asthma. Acta Allergologica. 1970;25(5):365-73. NDE. [pmid: 4101988].
Sobel. Treatment of grass pollenosis with various preparations: eleven-year study. Annals of Allergy. 1966;24(9):459-68. NRC. [pmid: 4380597].
Spaeth, Klimek L, Mosges R. Sedation in allergic rhinitis is caused by the condition and not by antihistamine treatment. Allergy. 1996;51(12):893-906. MAC. [pmid: 9020417].
Spangler, Abelson MB, Ober A, Gotnes PJ. Randomized, double-masked comparison of olopatadine ophthalmic solution, mometasone furoate monohydrate nasal spray, and fexofenadine hydrochloride tablets using the conjunctival and nasal allergen challenge models. Clin Ther. 2003;25(8):2245-67. NDE. [pmid: 14512132].
Storms, Pearlman DS, Chervinsky P, Grossman J, Halverson PC, Freitag JJ, Widlitz MD. Effectiveness of azelastine nasal solution in seasonal allergic rhinitis. Ear Nose Throat J. 1994;73(6):382-6. 390. 4. NRC. [pmid: 8076537].
Stricker, Nathan RA, Winder JA, Pepsin PJ, Rogenes PR, Westlund R, Cook CK. Fluticasone propionate aqueous nasal spray Fluticasone propionate and loratadine Loratadine, alone and in combination, in the treatment of fall seasonal allergic rhinitis SAR. Annals of Allergy, Asthma and Immunology. 1998;80:115. NDE.
Taegtmeyer, Steurer-Stey C, Spertini F, Bircher A, Helbling A, Miedinger D, Schafroth S, Scherer K, Leuppi JD. Allergic rhinitis in patients with asthma: the Swiss LARA (Link Allergic Rhinitis in Asthma) survey. Curr Med Res Opin. 2009;25(5):1073-80. NDE. [pmid: 19292600].
Takasaki, Enatsu K, Kumagami H, Takahashi H. Relationship between airborne pollen count and treatment outcome in Japanese cedar pollinosis patients. Eur Arch Otorhinolaryngol. 2009;266(5):673-6. NDE. [pmid: 18704471].
Taramarcaz, Gibson PG. Intranasal corticosteroids for asthma control in people with coexisting asthma and rhinitis. Cochrane Database Syst Rev. 2003;(4):CD003570. MAC. [pmid: 14583983].
Taramarcaz, Gibson PG. The effectiveness of intranasal corticosteroids in combined allergic rhinitis and asthma syndrome. Clin Exp Allergy. 2004;34(12):1883-9. NDE. [pmid: 15663563].
Topuz, Ogmen GG. Montelukast as an adjuvant to mainstay therapies in patients with seasonal allergic rhinitis. Clinical and Experimental Allergy. 2003;33(6):823-826. NDE. [pmid: 12801319].
Ural, Oktemer TK, Kizil Y, Ileri F, Uslu S. Impact of isotonic and hypertonic saline solutions on mucociliary activity in various nasal pathologies: clinical study. J Laryngol Otol. 2009;123(5):517-21. NRC. [pmid: 18957157].
van Bavel, Prillaman BA, Goode Sellers ST, Howland W, Jacobs RL, Martin BG, Cook CK, Rickard K. Fluticasone propionate aqueous nasal spray improves snoring in patients with sinus pain and pressure associated with nasal congestion due to allergic rhinitis. Annals of Allergy, Asthma & Immunology. 2001;86:113. NDE.
van Bavel, Ratner PH, Nayak AS, Shulan D, Reed KD, Rogenes PR, Cook CK. Ocular efficacy and clinician overall evaluation of intranasal fluticasone propionate Fluticasone propionate versus loratadine Loratadine in seasonal allergic rhinitis SAR. Annals of Allergy, Asthma and Immunology. 1997;78:128. NDE.
Vlastarakos, Manolopoulos L, Ferekidis E, Antsaklis A, Nikolopoulos TP. Treating common problems of the nose and throat in pregnancy: what is safe?. Eur Arch Otorhinolaryngol. 2008;265(5):499-508. NDE. [pmid: 18265995].
Von Maur. Antihistamine selection in patients with allergic rhinitis. Annals of Allergy. 1985;55(3):458-462. MAC. [pmid: 2864005].
Vuurman, van Veggel LM, Uiterwijk MM, Leutner D, O'Hanlon JF. Seasonal allergic rhinitis and antihistamine effects on children's learning. Ann Allergy. 1993;71(2):121-6. NDE. [pmid: 8346863].
Waddell, Patel SK, Toma AG, Maw AR. Intranasal steroid sprays in the treatment of rhinitis: is one better than another?. J Laryngol Otol. 2003;117(11):843-5. NRC. [pmid: 14670141].
Walker, Khan-Wasti S, Fletcher M, Cullinan P, Harris J, Sheikh A. Seasonal allergic rhinitis is associated with a detrimental effect on examination performance in United Kingdom teenagers: case-control study. Journal of Allergy & Clinical Immunology. 2007;120(2):381-7. NDE. [pmid: 17560637].
Wang, Smitz J, De Waele M, Clement P. Effect of topical applications of budesonide and azelastine on nasal symptoms, eosinophil count and mediator release in atopic patients after nasal allergen challenge during the pollen season. Int Arch Allergy Immunol. 1997;114(2):185-92. NDE. [pmid: 9338613].
Wang, Clement P, Smitz J, De Waele M. The activity of recent anti-allergic drugs in the treatment of seasonal allergic rhinitis. Acta Otorhinolaryngol Belg. 1996;50(1):25-32. NDE. [pmid: 8669268].
Weiler, Meltzer EO, Benson PM, Weiler K, Widlitz MD, Freitag J. A dose-ranging study of the efficacy and safety of azelastine nasal spray in the treatment of seasonal allergic rhinitis with an acute model. J Allergy Clin Immunol. 1994;94(6 Pt 1):972-80. NRC. [pmid: 7798545].
Weiler, Bloomfield JR, Woodworth GG, Grant AR, Layton TA, Brown TL, McKenzie DR, Baker TW, Watson GS. Effects of fexofenadine, diphenhydramine, and alcohol on driving performance. A randomized, placebo-controlled trial in the Iowa driving simulator. Ann Intern Med. 2000;132(5):354-63. NRC. [pmid: 10691585].
Weiner, Abramson MJ, Puy RM. Intranasal corticosteroids versus oral H1 receptor antagonists in allergic rhinitis: systematic review of randomised controlled trials. BMJ. 1998;317(7173):1624-9. NRC. [pmid: 9848901].
Weinstein, O'Brien S, Weinstein AM. A regimen of chlorpheniramine at night and pseudoephedrine during the day for allergic rhinitis; comparison with fexofenadine twice daily. Annals of Allergy, Asthma and Immunology. 1998;80:109. NDE.
Wheatley. A corticosteroid nasal spray in hayfever. Current therapeutic research, clinical and experimental. 1976;19(6):612-21. NDE.
Wilken, Kane RL, Ellis AK, Rafeiro E, Briscoe MP, Sullivan CL, Day JH. A comparison of the effect of diphenhydramine and desloratadine on vigilance and cognitive function during treatment of ragweed-induced allergic rhinitis. Ann Allergy Asthma Immunol. 2003;91(4):375-85. NDE. [pmid: 14582817].
Williams, Hull H, McSorley P, Frosolono MF, Sanders RL. Efficacy of acrivastine plus pseudoephedrine for symptomatic relief of seasonal allergic rhinitis due to mountain cedar. Ann Allergy Asthma Immunol. 1996;76(5):432-8. NRC. [pmid: 8630717].
Wilson, Orr LC, Sims EJ, Lipworth BJ. Effects of monotherapy with intra-nasal corticosteroid or combined oral histamine and leukotriene receptor antagonists in seasonal allergic rhinitis. Clin Exp Allergy. 2001;31(1):61-8. NRC. [pmid: 11167952].
Wilson, Orr LC, Coutie WJ, Sims EJ, Lipworth BJ. A comparison of once daily fexofenadine versus the combination of montelukast plus loratadine on domiciliary nasal peak flow and symptoms in seasonal allergic rhinitis. Clin Exp Allergy. 2002;32(1):126-32. NRC. [pmid: 12002729].
Wilson, Dempsey OJ, Sims EJ, Lipworth BJ. Subjective and objective markers of treatment response in patients with seasonal allergic rhinitis. Annals of allergy, asthma & immunology: official publication of the American College of Allergy, Asthma, & Immunology. 2000;85(2):111-4. NRC.
Wilson, O'Byrne PM, Parameswaran K. Leukotriene receptor antagonists for allergic rhinitis: a systematic review and meta-analysis. Am J Med. 2004;116(5):338-44. NDE. [pmid: 14984820].
Wober, Rahlfs VW, Baehre M. Comparative efficacy and safety of azelastine and cromolyn sodium nasal sprays in seasonal allergic rhinitis. Annals of Allergy, Asthma and Immunology. 1999;82:110. NDE.
Wu, Li TH, Wang TY, Hsu CL, Chen CJ. A comparative study of loratadine syrup and cyproheptadine HCL solution for treating perennial allergic rhinitis in Taiwanese children aged 2-12 years. International Journal of Immunopathology & Pharmacology. 2012;25(1):231-7. NRD. [pmid: 22507335].
Yamamoto, Yamada T, Sakashita M, Kubo S, Susuki D, Tokunaga T, Ogi K, Terasawa Y, Yamashita S, Kayano Y, Masada M, Kimura Y, Fujieda S. Efficacy of prophylactic treatment with montelukast and montelukast plus add-on loratadine for seasonal allergic rhinitis. Allergy and Asthma Proceedings. 2012;33(2):e17-e22. NRC. [pmid: 22525385].
Yanai, Rogala B, Chugh K, Paraskakis E, Pampura AN, Boev R. Safety considerations in the management of allergic diseases: Focus on antihistamines. Current Medical Research and Opinion. 2012;28(4):623-642. NDE. [pmid: 22455874].
Yanez, Rodrigo GJ. Intranasal corticosteroids versus topical H1 receptor antagonists for the treatment of allergic rhinitis: a systematic review with meta-analysis. Ann Allergy Asthma Immunol. 2002;89(5):479-84. MSP. [pmid: 12452206].
Yariktas, Unlu M, Doner F, Sahin U. Comparison of leukotriene receptor antagonist and antihistamine therapy in seasonal allergic rhinitis. Turkish Archives of Otolaryngology. 2002;40(4):252-6. FLA.
Yen, Wang PC, Chang YL. Safety and efficacy of fexofenadine HCL (Allegra) in the treatment of allergic rhinitis: Clinical experience. Tzu Chi Medical Journal. 2002;14(5):295-300. FLA.