# Search Strategies

The following electronic databases were searched on July 18, 2012 for citations:

- MEDLINE® (1948 to July 18, 2012) yielded 1992 records
- EMBASE® (1980 to July 18, 2012) yielded 1621 records
- The Cochrane Library (through July 18, 2012) yielded 731 records

## MEDLINE

1. Rhinitis, Allergic, Perennial/
2. Rhinitis, Allergic, Seasonal/
3. Rhinitis/
4. (seasonal or allergic).tw.
5. 3 and 4
6. seasonal rhinitis.tw.
7. allergic rhinitis.tw.
8. (hay fever or hayfever).tw.
9. (sar or par).tw.
10. or/1-2,5-9
11. exp Adrenal Cortex Hormones/ or corticosteroid$.tw.
12. Betamethasone/ or (Betamethasone or Celestone).tw.
13. Cortisone/ or Cortone.tw.
14. exp Dexamethasone/ or (Dexamethasone or Baycadron or Hexadrol or Decadron or Dexium or Dexone or DexPak).tw.
15. exp Hydrocortisone/ or (Hydrocortisone or Cortef or Hydrocortone).tw.
16. Methylprednisolone/ or (Methylprednisolone or medrol).tw.
17. exp Prednisolone/ or (Prednisolone or asmalPred Plus or Millipred or Pediapred or Prelone or Veripred or Flo-Pred or Cotolone or Orapred or Prednoral).tw.
18. Prednisone/ or (Prednisone or Liquid Pred or Deltasone or Meticorten or Orasone or Prednicen or Sterapred or Prednicot).tw.
19. exp Triamcinolone/ or (Triamcinolone or Aristocort).tw.
20. or/11-17
21. exp Administration, Oral/ or oral$.tw.
22. 20 and 21
23. Beclomethasone/ or (Beclomethasone or Beconase or Vancenase).tw.
24. exp Adrenal Cortex Hormones/ or corticosteroid$.tw.
25. Budesonide/ or (Budesonide or Rhinocort).tw.
26. Pregnenediones/ or (Ciclesonide or Omnaris).tw.
27. exp Dexamethasone/ or (Dexamethasone or Dexacort).tw.
28. exp Fluocinolone Acetonide/ or (Flunisolide or Nasalide or Nasarel).tw.
29. exp Androstadienes/ or (Fluticasone or Flonase or Veramyst).tw.
30. (Mometasone or Nasonex).tw.
31. exp Triamcinolone/ or (Triamcinolone or AllerNaze or Nasocort or Tri-nasal).tw.
32. or/23-31
33. Administration, Intranasal/ or (nasal$ or intranasal$).tw.
34. 32 and 33
35. exp Histamine Antagonists/ or antihistamine$.tw.
36. Cetirizine/ or (Cetirizine or Zyrtec or Alleroff or Aller-tec).tw.
37. Loratadine/ or (Loratadine or Desloratadine or Clarinex or Claritin or Triaminic or Agistam or Alavert or Bactimicina allergy or Clear-atadine or Loradamed).tw.
38. Terfenadine/ or (Fexofenadine or Allegra).tw.
39. (Levocetirizine or Xyzal).tw.
40. or/36-39
41. exp Histamine Antagonists/ or antihistamine$.tw.
42. exp Brompheniramine/ or (Brompheniramine or Lodrane or Tridane or Bromaphen or Brovex or B-vex or Tanacof or Bidhist or Bromax or Respa or Brompsiro or Dimetane or Siltane or Vazol or Conex or J-Tan).tw.
43. Carbinoxamine.tw.
44. Pyridines/ or (Carbinoxamine or Carboxine or Cordron or Histuss or Palgic or Pediatex or Pediox or Arbinoxa).tw.
45. Chlorpheniramine/ or (Chlorpheniramine or Chlo-Amine or Chlor-Phen or Krafthist or Chlortan or Ed ChlorPed or P-Tann or Allerlief or Chlor-Al Rel or Myci Chlorped or Pediatan or Ahist or Aller-Chlor or Chlor-Mal or Chlor-Phenit or Diabetic Tussin or Ed Chlor Tan or Ridramin or Teldrin or Uni-Cortrom).tw.
46. Clemastine/ or (Clemastine or Tavist or Allerhist$ or Dayhist$).tw.
47. Cyproheptadine/ or (Cyproheptadine or Periactin).tw.
48. (Dexchlorpheniramine or Polaramine).tw.
49. exp Diphenhydramine/ or (Diphenhydramine or Benadryl or Dytan or Kids-eeze or Allergia$ or Benekraft or Diphenyl or Aler-Dryl or Altaryl or Antihist or Antituss or Beldin or Belix or Bromanate AF or Bydramine or Diphen or Diphenadryl or Diphenyl$ or Dytuss or Elixsure or Hydramine or Nu-med or Pardyl or PediaCare or Scot-Tussin or Syladryl or Silaphen or Tusstat or Theraflu or Ben Tann or Dicopanol or Allermax or Banophen or Diphedryl or Diphenhist or Nervine or Paxidorm).tw.
50. Doxylamine/ or (Doxylamine or Aldex or Doxytex).tw.
51. Promethazine/ or (Promethazine or Phenergan or Pentazine or Promacot).tw.
52. Triprolidine/ or (Triprolidine or Tripohist or Zymine).tw.
53. exp Dibenzoxepins/ or (Olopatadine or Patanase).tw.
54. exp Phthalazines/ or (Azelastine or Astelin or Astepro).tw.
55. or/41-54
56. Ipratropium/ or (Ipratropium or Atrovent).tw.
57. Cromolyn Sodium/ or (cromoglycate or Cromolyn or Nasalcrom).tw.
58. Leukotriene Antagonists/ or (Leukotriene Antagonist$ or Montelukast or Singulair).tw.
59. exp Nasal Decongestants/ or exp Phenylephrine/ or Imidazoles/ or (nasal decongestant$ or Levmetamfetamine or vapo?r inhaler$ or Naphazoline or Privine or Oxymetazoline or Afrin or (Allerest adj3 Nasal) or Dristan or Duramist plus or Four-Way or Mucinex Nasal or Nasin or Neo-Synephrine or Nostrilla or (NTZ adj3 Nasal) or Oxyfrin or Oxymeta or Sinarest or Zicam or Phenylephrine or Tetrahydrozoline or tyzine or (Alconefrin adj2 Decongestant) or Rhinall or 4-way or Sinex or Propylhexedrine or Benzedrex or Xylometazoline or Otrivin).tw.
60. (oral decongestant$ or Ah-chew$ or Gilchew or Phenyl-T or Despec or Lusonal).tw. or exp Pseudoephedrine/ or (Pseudoephedrine or Afrinol or Contac or Efidac or Suphedrine or Decofed or Elixsure or Ephed 60 or Kid Kare or Myfedrine or Q-Fed or Silfedrine or Superfed or Unifed or Entex or Nasofed or Congest Aid or Sudophed or Cenafed or Congestaclear or Pseudocot or Pseudofed or Pseudotabs or Pseudoval or Ridafed or Seudotabs or Sudafed or Sudodrin or Sudogest or Sudrine).tw.
61. sodium chloride/ or (saline or Altamist or ENTsol or Little Noses or nasal Moist or Ocean or Pretz or Salinex or SaltAire or Deep Sea or Humist or Marine mist or sea Mist or Nasosol or Pediamist or Rhinaris or Sea Soft).tw.
62. (Accuhist or Actacin or Actagen or Actamine or Actedril or Acticon or Actifed or Alacol or Ala-Hist or Alenaze-D or Allan Tannate or Allent or Aller-Chlor or Allercon or AllerDur or Allerest or Allerfrim or Allerx or Altafed or Amerifed or Anamine or Anaplex or Andec or Andehist or Aphedrid or A-Phedrin or Aridex-D or Atridine or Atrogen or Atrohist or Benylin or B-Fedrine or Bi-Tann or BP Allergy or BPM Pseudo or Brexin or Brofed or Brom Tann or Bromadrine or Bromaline or Bromaphedrine or Bromaxefed or BROMDEC or Bromfed or Bromfenex or Bromhist$ or BROMPHEN or C Tan D or Carbaxefed or CARBIC or Carbiset or Carbodec or Carbofed or Cardec or Centergy or Cetiri-d or Chemdec or Chlor Trimeton or Chlorafed$ or Chlordrine or Chlor-Mes or Chlorphedrin or Clorfed or Codimal$ or Coldec or Colfed$ or Cophene or CP Oral or CP Tannic or C-Phed Tannate or Curaler or Cydec or Dallergy or D-Amine or Dayquil Allergy or Deconamine or Decongestamine or De-Congestine or Deconomed or Delsym or Desihist or Dexaphen or Dexophed or Dicel or Dimetapp or Diphentann or Disobrom or Disophrol or Dixaphedrine or Drexophed or Drixomed or Drixoral or D-Tann or Duomine or Duotan or Dura Ron or Durafed or Duralex or Dura-Tap or Duratuss or Dynahist or Ed A-Hist or Endafed or Entre-B or Ex?Dec or Fedahist or Hayfebrol or Hexafed or Hisdec or Histadec or Histafed or Histalet or HistamaxD or Histatab or Hista-Tabs or Histex or Hydro-Tussin or Iofed or Isophen-DF or Klerist-D or Kronofed-A or Lohist or Lortuss or Maldec or Maxichlor or Med-Hist or M-Hist or Mintex or Mooredec or NalDex or Nalfed or Nasohist or ND Clear or NeutraHist or Nohist or Norel LA or Novafed or Novahistine Elixir or Ny-Tannic or Orlenta or Pediachlor or Pharmadrine or Phenabid or PHENAMETH or PHEN-TUSS or Phenyl Chlor Tan or Phenylhistine or Prohist or Pseudoephedrine-BM or Pseubrom or Pseuclor or QDall or Q-Tapp or R?Tann$ or Relera or Rescon or Respahist or Rhinabid or RhinaHist or Ricobid or Ridifed or Rinade$ or Rinate or Robitussin Night$ or Rondamine or Rondec or Rondex or Rymed or Ryna Liquid or Rynatan or Semprex or Seradex or Shellcap or Sildec or Sinuhist or Sonahist or Suclor or SudaHist or Sudal or Sudo Chlor or Suphenamine or SuTan or Tanabid or Tanafed or Tanahist or Tekral or Time-Hist or Touro or Triafed or Triphed or Tri-Pseudo or Triptifed or Trisofed or Tri-Sudo or Trisudrine or Trynate or Ultrabrom or Vazobid or Vazotab or V-Hist or Vi-Sudo or X-Hist or XiraHist or Zinx Chlor$ or Zotex).tw.
63. or/22,34,55,62
64. 10 and 63
65. randomized controlled trial.pt.
66. random$.tw.
67. 65 or 66
68. 64 and 67
69. (animals not humans).sh.
70. 68 not 69
71. limit 70 to english language
72. (“review” or “review academic” or “review tutorial”).pt.
73. (medline or medlars or embase or pubmed).tw,sh.
74. (scisearch or psychinfo or psycinfo).tw,sh.
75. (psychlit or psyclit).tw,sh.
76. cinahl.tw,sh.
77. ((hand adj2 search$) or (manual$ adj2 search$)).tw,sh.
78. (electronic database$ or bibliographic database$ or computeri?ed database$ or online database$).tw,sh.
79. (pooling or pooled or mantel haenszel).tw,sh.
80. (retraction of publication or retracted publication).pt.
81. (peto or dersimonian or der simonian or fixed effect).tw,sh.
82. or/73-81
83. 72 and 82
84. meta-analysis.pt.
85. meta-analysis.sh.
86. (meta-analys$ or meta analys$ or metaanalys$).tw,sh.
87. (systematic$ adj5 review$).tw,sh.
88. (systematic$ adj5 overview$).tw,sh.
89. (quantitativ$ adj5 review$).tw,sh.
90. (quantitativ$ adj5 overview$).tw,sh.
91. (quantitativ$ adj5 synthesis$).tw,sh.
92. (methodologic$ adj5 review$).tw,sh.
93. (methodologic$ adj5 overview$).tw,sh.
94. (integrative research review$ or research integration).tw.
95. or/84-94
96. 64 and 95
97. (animals not humans).sh.
98. 96 not 97
99. limit 98 to english language
100. placebo-controlled.tw.
101. (placebo and (control or controlled)).tw.
102. (observational or cohort or case-control or cross-sectional).tw.
103. or/100-102
104. 64 and 103
105. (animals not humans).sh.
106. 104 not 105
107. limit 106 to english language

## EMBASE

1. perennial rhinitis/
2. hay fever/
3. rhinitis/
4. (seasonal or allergic).tw.
5. 3 and 4
6. seasonal rhinitis.tw.
7. allergic rhinitis.tw.
8. (hay fever or hayfever).tw.
9. (sar or par).tw.
10. or/1-2,5-9
11. exp corticosteroid/ or corticosteroid$.tw.
12. Betamethasone/ or (Betamethasone or Celestone).tw.
13. Cortisone/ or Cortone.tw.
14. Dexamethasone/ or (Dexamethasone or Baycadron or Hexadrol or Decadron or Dexium or Dexone or DexPak).tw.
15. Hydrocortisone/ or (Hydrocortisone or Cortef or Hydrocortone).tw.
16. Methylprednisolone/ or (Methylprednisolone or medrol).tw.
17. Prednisolone/ or (Prednisolone or asmalPred Plus or Millipred or Pediapred or Prelone or Veripred or Flo-Pred or Cotolone or Orapred or Prednoral).tw.
18. Prednisone/ or (Prednisone or Liquid Pred or Deltasone or Meticorten or Orasone or Prednicen or Sterapred or Prednicot).tw.
19. Triamcinolone/ or (triamcinolone or Aristocort).tw.
20. oral drug administration/ or oral$.tw.
21. or/11-19
22. 20 and 21
23. Beclometasone/ or (Beclomet?asone or Beconase or Vancenase).tw.
24. exp corticosteroid/ or corticosteroid$.tw.
25. Budesonide/ or (Budesonide or Rhinocort).tw.
26. Ciclesonide/ or (Ciclesonide or Omnaris).tw.
27. Dexamethasone/ or (Dexamethasone or Dexacort).tw.
28. Flunisolide/ or (Flunisolide or Nasalide or Nasarel).tw.
29. Fluticasone/ or (Fluticasone or Flonase or Veramyst).tw.
30. mometasone furoate/ or (Mometasone or Nasonex).tw.
31. Triamcinolone/ or (Triamcinolone or AllerNaze or Nasocort or Tri-nasal).tw.
32. intranasal drug administration/ or (nasal$ or intranasal$).tw.
33. or/23-31
34. 32 and 33
35. exp antihistaminic agent/ or antihistamine$.tw.
36. Cetirizine/ or (Cetirizine or Zyrtec or Alleroff or Aller-tec).tw.
37. Loratadine/ or (Loratadine or Desloratadine or Clarinex or Claritin or Triaminic or Agistam or Alavert or Bactimicina allergy or Clear-atadine or Loradamed).tw.
38. Fexofenadine/ or (Fexofenadine or Allegra).tw.
39. Levocetirizine/ or (Levocetirizine or Xyzal).tw.
40. Brompheniramine/ or (Brompheniramine or Lodrane or Tridane or Bromaphen or Brovex or B-vex or Tanacof or Bidhist or Bromax or Respa or Brompsiro or Dimetane or Siltane or Vazol or Conex or J-Tan).tw.
41. Carbinoxamine/ or (Carboxine or Cordron or Histuss or Palgic or Pediatex or Pediox or Arbinoxa).tw.
42. Chlorpheniramine/ or (Chlorpheniramine or Chlo-Amine or Chlor-Phen or Krafthist or Chlortan or Ed ChlorPed or P-Tann or Allerlief or Chlor-Al Rel or Myci Chlorped or Pediatan or Ahist or Aller-Chlor or Chlor-Mal or Chlor-Phenit or Diabetic Tussin or Ed Chlor Tan or Ridramin or Teldrin or Uni-Cortrom).tw.
43. Clemastine/ or (Clemastine or Tavist or Allerhist$ or Dayhist$).tw.
44. Cyproheptadine/ or (Cyproheptadine or Periactin).tw.
45. Dexchlorpheniramine/ or (Dexchlorpheniramine or Polaramine).tw.
46. Diphenhydramine/ or (Diphenhydramine or Benadryl or Dytan or Kids-eeze or Allergia$ or Benekraft or Diphenyl or Aler-Dryl or Altaryl or Antihist or Antituss or Beldin or Belix or Bromanate AF or Bydramine or Diphen or Diphenadryl or Diphenyl$ or Dytuss or Elixsure or Hydramine or Nu-med or Pardyl or PediaCare or Scot-Tussin or Syladryl or Silaphen or Tusstat or Theraflu or Ben Tann or Dicopanol or Allermax or Banophen or Diphedryl or Diphenhist or Nervine or Paxidorm).tw.
47. Doxylamine/ or (Doxylamine or Aldex or Doxytex).tw.
48. Promethazine/ or (Promethazine or Phenergan or Pentazine or Promacot).tw.
49. Triprolidine/ or (Triprolidine or Tripohist or Zymine).tw.
50. Olopatadine/ or (Olopatadine or Patanase).tw.
51. Azelastine/ or (Azelastine or Astelin or Astepro).tw.
52. ipratropium bromide/ or (Ipratropium or Atrovent).tw.
53. cromoglycate disodium/ or (cromoglycate or Cromolyn or Nasalcrom).tw.
54. leukotriene receptor blocking agent/ or (Leukotriene Antagonist$ or Montelukast or Singulair).tw.
55. Decongestive agent/ or Phenylephrine/ or (nasal decongestant$ or Levmetamfetamine or vapo?r inhaler$ or Naphazoline or Privine or Oxymetazoline or Afrin or (Allerest adj3 Nasal) or Dristan or Duramist plus or Four-Way or Mucinex Nasal or Nasin or Neo-Synephrine or Nostrilla or (NTZ adj3 Nasal) or Oxyfrin or Oxymeta or Sinarest or Zicam or Phenylephrine or (Alconefrin adj2 Decongestant) or Rhinall or 4-way or Sinex or Propylhexedrine or Benzedrex or Xylometazoline or Otrivin or tetrahydrozoline or tyzine).tw.
56. Pseudoephedrine/ or (oral decongestant$ or Ah-chew$ or Gilchew or Phenyl-T or Despec or Lusonal or Pseudoephedrine or Afrinol or Contac or Efidac or Suphedrine or Decofed or Elixsure or Ephed 60 or Kid Kare or Myfedrine.tw. or Q-Fed or Silfedrine or Superfed or Unifed or Entex or Nasofed or Congest Aid or Sudophed or Cenafed or Congestaclear or Pseudocot or Pseudofed or Pseudotabs or Pseudoval or Ridafed or Seudotabs or Sudafed or Sudodrin or Sudogest or Sudrine).tw.
57. sodium chloride/ or (saline or Altamist or ENTsol or Little Noses or nasal Moist or Ocean or Pretz or Salinex or SaltAire or Deep Sea or Humist or Marine mist or sea Mist or Nasosol or Pediamist or Rhinaris or Sea Soft).tw.
58. (Accuhist or Actacin or Actagen or Actamine or Actedril or Acticon or Actifed or Alacol or Ala-Hist or Alenaze-D or Allan Tannate or Allent or Aller-Chlor or Allercon or AllerDur or Allerest or Allerfrim or Allerx or Altafed or Amerifed or Anamine or Anaplex or Andec or Andehist or Aphedrid or A-Phedrin or Aridex-D or Atridine or Atrogen or Atrohist or Benylin or B-Fedrine or Bi-Tann or BP Allergy or BPM Pseudo or Brexin or Brofed or Brom Tann or Bromadrine or Bromaline or Bromaphedrine or Bromaxefed or BROMDEC or Bromfed or Bromfenex or Bromhist$ or BROMPHEN or C Tan D or Carbaxefed or CARBIC or Carbiset or Carbodec or Carbofed or Cardec or Centergy or Cetiri-d or Chemdec or Chlor Trimeton or Chlorafed$ or Chlordrine or Chlor-Mes or Chlorphedrin or Clorfed or Codimal$ or Coldec or Colfed$ or Cophene or CP Oral or CP Tannic or C-Phed Tannate or Curaler or Cydec or Dallergy or D-Amine or Dayquil Allergy or Deconamine or Decongestamine or De-Congestine or Deconomed or Delsym or Desihist or Dexaphen or Dexophed or Dicel or Dimetapp or Diphentann or Disobrom or Disophrol or Dixaphedrine or Drexophed or Drixomed or Drixoral or D-Tann or Duomine or Duotan or Dura Ron or Durafed or Duralex or Dura-Tap or Duratuss or Dynahist or Ed A-Hist or Endafed or Entre-B or Ex?Dec or Fedahist or Hayfebrol or Hexafed or Hisdec or Histadec or Histafed or Histalet or HistamaxD or Histatab or Hista-Tabs or Histex or Hydro-Tussin or Iofed or Isophen-DF or Klerist-D or Kronofed-A or Lohist or Lortuss or Maldec or Maxichlor or Med-Hist or M-Hist or Mintex or Mooredec or NalDex or Nalfed or Nasohist or ND Clear or NeutraHist or Nohist or Norel LA or Novafed or Novahistine Elixir or Ny-Tannic or Orlenta or Pediachlor or Pharmadrine or Phenabid or PHENAMETH or PHEN-TUSS or Phenyl Chlor Tan or Phenylhistine or Prohist or Pseudoephedrine-BM or Pseubrom or Pseuclor or QDall or Q-Tapp or R?Tann$ or Relera or Rescon or Respahist or Rhinabid or RhinaHist or Ricobid or Ridifed or Rinade$ or Rinate or Robitussin Night$ or Rondamine or Rondec or Rondex or Rymed or Ryna Liquid or Rynatan or Semprex or Seradex or Shellcap or Sildec or Sinuhist or Sonahist or Suclor or SudaHist or Sudal or Sudo Chlor or Suphenamine or SuTan or Tanabid or Tanafed or Tanahist or Tekral or Time-Hist or Touro or Triafed or Triphed or Tri-Pseudo or Triptifed or Trisofed or Tri-Sudo or Trisudrine or Trynate or Ultrabrom or Vazobid or Vazotab or V-Hist or Vi-Sudo or X-Hist or XiraHist or Zinx Chlor$ or Zotex).tw.
59. or/22,34-58
60. 10 and 59
61. limit 60 to randomized controlled trial
62. random$.tw.
63. 60 and 62
64. 61 or 63
65. (animal$ not human$).sh,hw.
66. 64 not 65
67. limit 66 to english language
68. exp side effect/
69. side effect$.tw.
70. undesirable effect$.tw.
71. tolerability.tw.
72. exp toxicity/
73. (adverse adj2 (effect$ or reaction$ or event$ or outcome$)).ti.
74. exp adverse drug reaction/
75. or/69-74
76. 60 and 75
77. (animal$ not human$).sh,hw.
78. 76 not 77
79. limit 78 to english language
80. exp review/
81. (literature adj3 review$).ti,ab.
82. exp meta analysis/
83. exp “Systematic Review”/
84. or/80-83
85. (medline or medlars or embase or pubmed or cinahl or amed or psychlit or psyclit or psychinfo or psycinfo or scisearch or cochrane).ti,ab.
86. RETRACTED ARTICLE/
87. 85 or 86
88. 84 and 87
89. (systematic$ adj2 (review$ or overview)).ti,ab.
90. (meta?anal$ or meta anal$ or meta-anal$ or metaanal$ or metanal$).ti,ab.
91. or/88-90
92. 60 and 91
93. (animal$ not human$).sh,hw.
94. 92 not 93
95. limit 94 to english language

## Cochrane Library

ID | Search
#1 | MeSH descriptor Rhinitis, Allergic, Perennial, this term only
#2 | MeSH descriptor Rhinitis, Allergic, Seasonal, this term only
#3 | MeSH descriptor Rhinitis, this term only
#4 | (seasonal or allergic):ti,ab
#5 | (#3 AND #4)
#6 | “seasonal rhinitis”:ti,ab
#7 | “allergic rhinitis”:ti,ab
#8 | (hay fever or hayfever):ti,ab
#9 | (sar or par):ti,ab
#10 | (#1 OR #2 OR #5 OR #6 OR #7 OR #8 OR #9)
#11 | MeSH descriptor Adrenal Cortex Hormones explode all trees
#12 | corticosteroid*:ti,ab
#13 | MeSH descriptor Betamethasone, this term only
#14 | (Betamethasone or Celestone):ti,ab
#15 | MeSH descriptor Cortisone, this term only
#16 | Cortone:ti,ab
#17 | MeSH descriptor Dexamethasone explode all trees
#18 | (Dexamethasone or Baycadron or Hexadrol or Decadron or Dexium or Dexone or DexPak):ti,ab
#19 | MeSH descriptor Hydrocortisone explode all trees
#20 | (Hydrocortisone or Cortef or Hydrocortone):ti,ab
#21 | MeSH descriptor Methylprednisolone, this term only
#22 | (Methylprednisolone or medrol):ti,ab
#23 | MeSH descriptor Prednisolone, this term only
#24 | (Prednisolone or asmalPred Plus or Millipred or Pediapred or Prelone or Veripred or Flo-Pred or Cotolone or Orapred or Prednoral):ti,ab
#25 | MeSH descriptor Prednisone, this term only
#26 | (Prednisone or Liquid Pred or Deltasone or Meticorten or Orasone or Prednicen or Sterapred or Prednicot):ti,ab
#27 | MeSH descriptor Triamcinolone, this term only
#28 | (triamcinolone or Aristocort):ti,ab
#29 | MeSH descriptor Administration, Oral explode all trees
#30 | oral*:ti,ab
#31 | (#11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29)
#32 | (#30 OR #31)
#33 | (#31 AND #32)
#34 | MeSH descriptor Beclomethasone, this term only
#35 | (Beclomet?asone or Beconase or Vancenase):ti,ab
#36 | MeSH descriptor Adrenal Cortex Hormones explode all trees
#37 | corticosteroid*:ti,ab
#38 | MeSH descriptor Budesonide, this term only
#39 | (Budesonide or Rhinocort):ti,ab
#40 | MeSH descriptor Pregnenediones, this term only
#41 | (Ciclesonide or Omnaris):ti,ab
#42 | MeSH descriptor Dexamethasone explode all trees
#43 | (Dexamethasone or Dexacort):ti,ab
#44 | MeSH descriptor Fluocinolone Acetonide explode all trees
#45 | (Flunisolide or Nasalide or Nasarel):ti,ab
#46 | MeSH descriptor Androstadienes explode all trees
#47 | (Fluticasone or Flonase or Veramyst):ti,ab
#48 | (Mometasone or Nasonex):ti,ab
#49 | MeSH descriptor Triamcinolone explode all trees
#50 | (Triamcinolone or AllerNaze or Nasocort or Tri-nasal):ti,ab
#51 | MeSH descriptor Administration, Intranasal, this term only
#52 | (nasal* or intranasal*):ti,ab
#53 | (#34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50)
#54 | (#51 OR #52)
#55 | (#53 AND #54)
#56 | MeSH descriptor Histamine Antagonists explode all trees
#57 | antihistamine*:ti,ab
#58 | MeSH descriptor Cetirizine, this term only
#59 | (Cetirizine or Zyrtec or Alleroff or Aller-tec):ti,ab
#60 | MeSH descriptor Loratadine, this term only
#61 | (Loratadine or Desloratadine or Clarinex or Claritin or Triaminic or Agistam or Alavert or “Bactimicina allergy” or Clear-atadine or Loradamed):ti,ab
#62 | MeSH descriptor Terfenadine, this term only
#63 | (Fexofenadine or Allegra):ti,ab
#64 | (Levocetirizine or Xyzal):ti,ab
#65 | MeSH descriptor Brompheniramine explode all trees
#66 | (Brompheniramine or Lodrane or Tridane or Bromaphen or Brovex or B-vex or Tanacof or Bidhist or Bromax or Respa or Brompsiro or Dimetane or Siltane or Vazol or Conex or J-Tan):ti,ab
#67 | Carbinoxamine:ti,ab
#68 | MeSH descriptor Pyridines, this term only
#69 | (Carbinoxamine or Carboxine or Cordron or Histuss or Palgic or Pediatex or Pediox or Arbinoxa):ti,ab
#70 | MeSH descriptor Chlorpheniramine, this term only
#71 | (Chlorpheniramine or Chlo-Amine or Chlor-Phen or Krafthist or Chlortan or “Ed ChlorPed” or P-Tann or Allerlief or “Chlor-Al Rel” or “Myci Chlorped” or Pediatan or Ahist or Aller-Chlor or Chlor-Mal or Chlor-Phenit or “Diabetic Tussin” or “Ed Chlor Tan” or Ridramin or Teldrin or Uni-Cortrom):ti,ab
#72 | MeSH descriptor Clemastine, this term only
#73 | (Clemastine or Tavist or Allerhist* or Dayhist*):ti,ab
#74 | MeSH descriptor Cyproheptadine, this term only
#75 | (Cyproheptadine or Periactin):ti,ab
#76 | (Dexchlorpheniramine or Polaramine):ti,ab
#77 | MeSH descriptor Diphenhydramine explode all trees
#78 | (Diphenhydramine or Benadryl or Dytan or Kids-eeze or Allergia* or Benekraft or or Bydramine or Diphen or Diphenadryl or Diphenyl* or Dytuss or Elixsure or Hydramine or Nu-med or Pardyl or PediaCare or Scot-Tussin or Syladryl or Silaphen or Tusstat or Theraflu or “Ben Tann” or Dicopanol or Allermax or Banophen or Diphedryl or Diphenhist or Nervine or Paxidorm):ti,ab
#79 | MeSH descriptor Doxylamine, this term only
#80 | (Doxylamine or Aldex or Doxytex):ti,ab
#81 | MeSH descriptor Promethazine, this term only
#82 | (Promethazine or Phenergan or Pentazine or Promacot):ti,ab
#83 | MeSH descriptor Triprolidine, this term only
#84 | (Triprolidine or Tripohist or Zymine):ti,ab
#85 | MeSH descriptor Dibenzoxepins explode all trees
#86 | (Olopatadine or Patanase):ti,ab
#87 | MeSH descriptor Phthalazines explode all trees
#88 | (Azelastine or Astelin or Astepro):ti,ab
#89 | MeSH descriptor Ipratropium, this term only
#90 | (Ipratropium or Atrovent):ti,ab
#91 | MeSH descriptor Cromolyn Sodium, this term only
#92 | (cromoglycate or Cromolyn or Nasalcrom):ti,ab
#93 | MeSH descriptor Leukotriene Antagonists, this term only
#94 | (“Leukotriene Antagonist*” or Montelukast or Singulair):ti,ab
#95 | MeSH descriptor Nasal Decongestants explode all trees
#96 | MeSH descriptor Phenylephrine, this term only
#97 | (nasal decongestant* or Levmetamfetamine or “vapo?r inhaler*” or Naphazoline or Four-Way or “Mucinex Nasal” or Nasin or Neo-Synephrine or Nostrilla or (NTZ near/3 Nasal) or Oxyfrin or Oxymeta or Sinarest or Zicam or Phenylephrine or (Alconefrin near/2 Decongestant) or Rhinall or 4-way or Sinex or Propylhexedrine or Benzedrex or Xylometazoline or Otrivin or tetrahydrozoline or tyzine):ti,ab
#98 | MeSH descriptor Pseudoephedrine, this term only
#99 | oral decongestant* or Ah-chew* or Gilchew or Phenyl-T or Despec or Lusonal or Pseudoephedrine or Afrinol or Contac or Efidac or Suphedrine or Decofed or Elixsure or “Ephed 60” or “Kid Kare” or Myfedrine or Q-Fed or Silfedrine or Superfed or Unifed or Entex or Nasofed or Congest Aid or Sudophed or Cenafed or Congestaclear or Pseudocot or Pseudofed or Pseudotabs or Pseudoval or Ridafed or Seudotabs or Sudafed or Sudodrin or Sudogest or Sudrine):ti,ab
#100 | MeSH descriptor Sodium Chloride, this term only
#101 | (saline or Altamist or ENTsol or “Little Noses” or n“asal Moist” or Ocean or Pretz or Salinex or SaltAire or “Deep Sea” or Humist or “Marine mist” or “sea Mist” or Nasosol or Pediamist or Rhinaris or “Sea Soft”):ti,ab
#102 | (Accuhist or Actacin or Actagen or Actamine or Actedril or Acticon or Actifed or Alacol or Ala-Hist or Alenaze-D or “Allan Tannate” or Allent or Aller-Chlor or Allercon or AllerDur or Allerest or Allerfrim or Allerx or Altafed or Amerifed or Anamine or Anaplex or Andec or Andehist or Aphedrid or A-Phedrin or Aridex-D or Atridine or Atrogen or Atrohist or Benylin or B-Fedrine or Bi-Tann or “BP Allergy” or “BPM Pseudo” or Brexin or Brofed or “Brom Tann” or Bromadrine or Bromaline or Bromaphedrine or Bromaxefed or BROMDEC or Bromfed or Bromfenex or Bromhist* or BROMPHEN or “C Tan D” or Carbaxefed or CARBIC or Carbiset or Carbodec or Carbofed or Cardec or Centergy or Cetiri-d or Chemdec or “Chlor Trimeton” or Chlorafed* or Chlordrine or Chlor-Mes or Chlorphedrin or Clorfed or Codimal* or Coldec or Colfed$ or Cophene or “CP Oral” or “CP Tannic” or C-Phed Tannate or Curaler or Cydec or Dallergy or D-Amine or Dayquil Allergy or Deconamine or Decongestamine or De-Congestine or Deconomed or Delsym or Desihist or Dexaphen or Dexophed or Dicel or Dimetapp or Diphentann or Disobrom or Disophrol or Dixaphedrine or Drexophed or Drixomed or Drixoral or D-Tann or Duomine or Duotan or Dura Ron or Durafed or Duralex or Dura-Tap or Duratuss or Dynahist or Ed A-Hist or Endafed or Entre-B or Ex?Dec or Fedahist or Hayfebrol or Hexafed or Hisdec or Histadec or Histafed or Histalet or HistamaxD or Histatab or Hista-Tabs or Histex or Hydro-Tussin or Iofed or Isophen-DF or Klerist-D or Kronofed-A or Lohist or Lortuss or Maldec or Maxichlor or Med-Hist or M-Hist or Mintex or Mooredec or NalDex or Nalfed or Nasohist or “ND Clear” or NeutraHist or Nohist or “Norel LA” or Novafed or Novahistine Elixir or Ny-Tannic or Orlenta or Pediachlor or Pharmadrine or Phenabid or PHENAMETH or PHEN-TUSS or Phenyl “Chlor Tan” or Phenylhistine or Prohist or Pseudoephedrine-BM or Pseubrom or Pseuclor or QDall or Q-Tapp or R?Tann$ or Relera or Rescon or Respahist or Rhinabid or RhinaHist or Ricobid or Ridifed or Rinade* or Rinate or “Robitussin Night*” or Rondamine or Rondec or Rondex or Rymed or “Ryna Liquid” or Rynatan or Semprex or Seradex or Shellcap or Sildec or Sinuhist or Sonahist or Suclor or SudaHist or Sudal or Sudo Chlor or Suphenamine or SuTan or Tanabid or Tanafed or Tanahist or Tekral or Time-Hist or Touro or Triafed or Triphed or Tri-Pseudo or Triptifed or Trisofed or Tri-Sudo or Trisudrine or Trynate or Ultrabrom or Vazobid or Vazotab or V-Hist or Vi-Sudo or X-Hist or XiraHist or “Zinx Chlor*” or Zotex):ti,ab
#103 | (#33 OR #55 OR #56 OR #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 OR #65 OR #66 OR #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 OR #78 OR #79 OR #80 OR #81 OR #82 OR #83 OR #84 OR #85 OR #86 OR #87 OR #88 OR #89 OR #90 OR #91 OR #92 OR #93 OR #94 OR #95 OR #96 OR #97 OR #98 OR #99 OR #100 OR #101 OR #102)
#104 | (#10 AND #103)

## Search Strategy for Gray Literature

### Regulatory Information

#### FDA (Drugs@FDA)

- Source: http://www.accessdata.fda.gov/scripts/cder/drugsatfda/
  Date searched: 4/11/2012
  Search strategy: All drugs in review scope searched by generic name
  Records: 0

### Clinical Trial Registries

#### ClinicalTrials.gov

- Source: http://clinicaltrials.gov/
  Date searched: 4/5/2012
  Search strategy: Seasonal Allergic rhinitis (category search)
  Records: 32

#### Current Controlled Trials

- Source: http://www.controlled-trials.com/
  Date searched: 4/12/2012
  Search strategy: “Allergic rhinitis” OR (Seasonal AND rhinitis) OR “Hay fever” OR Hayfever OR Pollen
  Records: 24

#### WHO International Clinical Trials Registry Platform Results

- Source: http://www.who.int/ictrp/en/
  Date searched: 4/5/2012
  Search strategy: Allergic rhinitis OR Seasonal OR Rhinitis OR “Hay fever” OR Hayfever OR Pollen
  Records: 11

### Conference Papers and Abstracts

#### Conferences and Association Meetings

- Source:
  - American Academy of Allergy, Asthma & Immunology (AAAAI): www.aaaai.org
  - British Society for Allergy and Clinical Immunology (BSACI): www.bsaci.org/
  Date searched: 4/5/2012
  Search strategy: Not applicable
  Records: 1

#### Scopus

- Source: http://www.scopus.com/home.url
  [underlined: Date searched: 4/11/2012]
  Search strategy: (TITLE-ABS-KEY(seasonal W/2 rhinitis)) OR (TITLE-ABS-KEY(“allergic rhinitis”)) OR (TITLE-ABS-KEY(“hay fever” OR hayfever)) OR (TITLE-ABS-KEY(pollen))) AND (((TITLE-ABS-KEY(corticosteroid* OR betamethasone OR celestone OR cortisone OR cortone OR dexamethasone OR baycadron OR hexadrol OR decadron OR dexium OR dexone OR dexpak OR hydrocortisone OR cortef OR hydrocortone OR methylprednisolone OR medrol OR prednisolone OR “asmalPred Plus” OR millipred OR pediapred OR prelone OR veripred OR flo-pred OR cotolone OR orapred OR prednoral OR prednisone OR liquid pred OR deltasone OR meticorten OR orasone OR prednicen OR sterapred OR prednicot OR triamcinolone OR aristocort)) OR (TITLE-ABS-KEY(beclomethasone OR beconase OR vancenase OR budesonide OR rhinocort OR ciclesonide OR omnaris OR dexamethasone OR dexacort OR flunisolide OR nasalide OR nasarel OR fluticasone OR flonase OR veramyst OR mometasone OR nasonex OR triamcinolone orallernaze OR nasocort OR tri-nasal)) OR (TITLE-ABS-KEY(antihistamine* OR cetirizine OR zyrtec OR alleroff OR aller-tec OR loratadine OR desloratadine OR clarinex OR claritin OR triaminic OR agistam OR alavert OR bactimicina allergy OR clear-atadine OR loradamed OR fexofenadine OR allegra OR levocetirizine OR xyzal orbrompheniramine OR lodrane OR tridane OR bromaphen OR brovex OR b-vex OR tanacof OR bidhist OR bromax OR respa OR brompsiro OR dimetane OR siltane OR vazol OR conex OR j-tan)) OR (TITLE-ABS-KEY(carbinoxamine OR carboxine OR cordron OR histuss OR palgic OR pediatex OR pediox OR arbinoxa OR chlorpheniramine OR chlo-amine OR chlor-phen OR krafthist OR chlortan OR “Ed ChlorPed” OR p-tann OR allerlief OR “Chlor-Al Rel” OR “Myci Chlorped” OR pediatan OR ahist OR aller-chlor OR chlor-mal OR chlor-phenit OR “Diabetic Tussin” OR “Ed Chlor Tan” OR ridramin OR teldrin OR uni-cortrom)) OR (TITLE-ABS-KEY(clemastine OR tavist OR allerhist* OR dayhist*))) OR ((TITLE-ABS-KEY(cyproheptadine OR periactin)) OR (TITLE-ABS-KEY(diphenhydramine OR benadryl OR dytan OR kids-eeze OR allergia* OR benekraft OR diphenyl OR aler-dryl OR altaryl OR antihist OR antituss OR beldin OR belix OR “Bromanate AF” OR bydramine OR diphen OR diphenadryl OR diphenyl* OR dytuss OR elixsure OR hydramine OR nu-med OR pardyl OR pediacare OR scot-tussin OR syladryl OR silaphen OR tusstat OR theraflu OR “Ben Tann” OR dicopanol OR allermax OR banophen OR diphedryl OR diphenhist OR nervine OR paxidorm)) OR (TITLE-ABS-KEY(doxylamine OR aldex OR doxytex)) OR (TITLE-ABS-KEY(promethazine OR phenergan OR pentazine OR promacot)) OR (TITLE-ABS-KEY(triprolidine OR tripohist OR zymine))) OR ((TITLE-ABS-KEY(olopatadine OR patanase)) OR (TITLE-ABS-KEY(azelastine OR astelin OR astepro)) OR (TITLE-ABS-KEY(ipratropium OR atrovent)) OR (TITLE-ABS-KEY(ipratropium OR atrovent))) OR ((TITLE-ABS-KEY(“Leukotriene Antagonist*” OR montelukast OR singulair)) OR (TITLE-ABS-KEY(“nasal decongestant*” OR levmetamfetamine OR “vapo?r inhaler*” OR naphazoline OR privine OR oxymetazoline OR afrin OR dristan OR “Duramist plus” OR “Four-Way” OR “Mucinex Nasal” OR nasin OR neo-synephrine OR nostrilla OR oxyfrin OR oxymeta OR sinarest OR zicam OR phenylephrine OR tetrahydrozoline OR tyzine OR rhinall OR 4-way OR sinex OR propylhexedrine OR benzedrex OR xylometazoline OR otrivin)) OR (TITLE-ABS-KEY(allerest W/3 nasal) OR TITLE-ABS-KEY(ntz W/3 nasal) OR TITLE-ABS-KEY(alconefrin adj2 decongestant)) OR (TITLE-ABS-KEY(“oral decongestant*” OR ah-chew* OR gilchew OR phenyl-t OR despec OR lusonal)) OR (TITLE-ABS-KEY(pseudoephedrine OR afrinol OR contac OR efidac OR suphedrine OR decofed OR elixsure OR “Ephed 60” OR “Kid Kare” OR myfedrine OR q-fed OR silfedrine OR superfed OR unifed OR entex OR nasofed OR “Congest Aid” OR sudophed OR cenafed OR congestaclear OR pseudocot OR pseudofed OR pseudotabs OR pseudoval OR ridafed OR seudotabs OR sudafed OR sudodrin OR sudogest OR sudrine))) OR ((TITLE-ABS-KEY(“sodium chloride” orsaline OR altamist OR “ENTsol” OR “Little Noses” OR “nasal Moist” OR ocean OR pretz OR salinex OR saltaire OR “Deep Sea” OR humist OR “Marine mist” OR “sea Mist” OR nasosol OR pediamist OR rhinaris OR “Sea Soft”)) OR (TITLE-ABS-KEY(accuhist OR actacin OR actagen OR actamine OR actedril OR acticon OR actifed OR alacol OR ala-hist OR alenaze-d OR “Allan Tannate” OR allent OR aller-chlor OR allercon OR allerdur OR allerest OR allerfrim OR allerx OR altafed OR amerifed OR anamine OR anaplex OR andec OR andehist OR aphedrid OR a-phedrin OR aridex-d OR atridine OR atrogen OR atrohist OR benylin OR b-fedrine OR bi-tann OR “BP Allergy” OR “BPM Pseudo” OR brexin OR brofed OR “Brom Tann” OR bromadrine OR bromaline OR bromaphedrine OR bromaxefed OR bromdec OR bromfed OR bromfenex OR bromhist* OR bromphen OR “C Tan D” OR carbaxefed OR carbic OR carbiset OR carbodec OR carbofed OR cardec OR centergy OR cetiri-d OR chemdec OR “Chlor Trimeton” OR chlorafed* OR chlordrine OR chlor-mes OR chlorphedrin OR clorfed OR codimal* OR coldec OR colfed* OR cophene OR “CP Oral” OR “CP Tannic” OR “C-Phed Tannate” OR curaler OR cydec OR dallergy OR d-amine OR “Dayquil Allergy” OR deconamine OR decongestamine OR de-congestine OR deconomed OR delsym OR desihist OR dexaphen OR dexophed OR dicel OR dimetapp OR diphentann OR disobrom OR disophrol OR dixaphedrine OR drexophed OR drixomed OR drixoral OR d-tann OR duomine OR duotan OR “Dura Ron” OR durafed OR duralex OR dura-tap OR duratuss OR dynahist OR “Ed A-Hist” OR endafed OR entre-b OR ex?dec OR fedahist OR hayfebrol OR hexafed OR hisdec OR histadec OR histafed OR histalet OR histamaxd OR histatab OR hista-tabs OR histex OR hydro-tussin OR iofed OR isophen-df OR klerist-d OR kronofed-a OR lohist OR lortuss OR maldec OR maxichlor OR med-hist OR m-hist OR mintex OR mooredec OR naldex OR nalfed OR nasohist OR “ND Clear” OR neutrahist OR nohist OR “Norel LA” OR novafed OR “Novahistine Elixir” OR ny-tannic OR orlenta OR pediachlor OR pharmadrine OR phenabid OR phenameth OR phen-tuss OR “Phenyl Chlor Tan” OR phenylhistine OR prohist OR pse-bm OR pseubrom OR pseuclor OR qdall OR q-tapp OR r?tann* OR relera OR rescon OR respahist OR rhinabid OR rhinahist OR ricobid OR ridifed OR rinade* OR rinate OR “Robitussin Night*” OR rondamine OR rondec OR rondex OR rymed OR “Ryna Liquid” OR rynatan OR semprex OR seradex OR shellcap OR sildec OR sinuhist OR sonahist OR suclor OR sudahist OR sudal OR “Sudo Chlor” OR suphenamine OR “SuTan” OR tanabid OR tanafed OR tanahist OR tekral OR time-hist OR touro OR triafed OR triphed OR tri-pseudo OR triptifed OR trisofed OR tri-sudo OR trisudrine OR trynate OR ultrabrom OR vazobid OR vazotab OR v-hist OR vi-sudo OR x-hist OR xirahist OR “Zinx Chlor*” OR zotex)))) AND (LIMIT-TO(DOCTYPE, “cp”))
  Records: 117

### Government Documents

#### AHRQ Effective Health Care Program

- Source: http://effectivehealthcare.ahrq.gov/
  Date searched: 4/12/2012
  Search strategy: Allergies in Health Condition
  Records: 2

#### AHRQ Home Page

- Source: http://www.ahrq.gov/
  Date searched: 4/16/2012
  Search strategy: “seasonal allergic”
  Records: 0

#### NIH Reporter

- Source: http://projectreporter.nih.gov/reporter.cfm
  Date searched: 4/16/2012
  Search strategy: Category: Allergic Rhinitis (Hay Fever), Text search: rhinitis, Text search: seasonal, Text search: “hay fever” OR hayfever
  Records: 0

### Manufacturer Database

- Source: Sanofi
  Date posted: 5/7/2012
  Search strategy: Not applicable
  Records: 80
- Source: Merck
  Date posted: 5/7/2012
  Search strategy: Not applicable
  Records: 57
- Source: Sunovion
  Date posted: 5/7/2012
  Search strategy: Not applicable
  Records: 39
- Source: McNeil
  Date posted: 5/7/2012
  Search strategy: Not applicable
  Records: 160