# Abbreviations

AZE: Azelastine
BDP: Beclomethasone dipropionate
BUD: Budesonide
C: Congestion
CET: Cetirizine
CI: Confidence interval
CLM: Clemastine
CHL: Chlorpheniramine
CRS: Cromolyn
DES: Desloratadine
DEX: Dexchlorpheniramine
FEV_1_: Forced expired volume in one second
FEX: Fexofenadine
FLU: Flunisolide
FF: Fluticasone furoate
FP: Fluticasone propionate
I: Itching
INCS: Intranasal corticosteroid
LOR: Loratadine
LCT: Levocetirizine
LRA: Leukotriene receptor antagonist
MCID: Minimum clinically important difference
MOD: Moderate
MF: Mometasone furoate
NR: Not reported
NS: Not significant
OLO: Olopatadine
PGA: Patient Global Assessment
PSE: Pseudoephedrine
QoL: Quality of life
R: Rhinorrhea
RCT: Randomized controlled trial
RQLQ: Rhinitis Quality of Life Questionnaire
S: Sneezing
SD: Standard deviation
SE: Standard error
SEV: Severe
TA: Triamcinolone acetonide
TASS: Total asthma symptom score
TNSS: Total nasal symptom score
TOSS: Total ocular symptom score
UNC: Uncertain
UNS: Unspecified
VAS: Visual analog scale