# Abbreviations

Alendr | Alendronate
Calcit | Calcitonin
CI | Confidence Interval
Esoph | Esophagus
Estrog | Estrogen
Etidro | Etidronate
GI | Gastrointestinal
HERS | Heart and Estrogen-Progestin Replacement Study
Ibandr | Ibandronate
Inj/app site rxns | Injection/ application site
Iu or IU | International Units
IV | Intravenous
LFTs | Liver function tests
MPR | Medication possession ratio
N/V | Nausea/vomiting
OR | Odds ratio
Pamidr | Pamidronate
PTH | Parathyroid hormone
Ralox | Raloxifene
RCT | Randomized Controlled Trial
RD | Rate difference
Rflx or esoph sx | Reflux or esophageal symptoms
Risedr | Risedonate
RR | Relative risk
Tamox | Tamoxifen
Testos | Testosterone
UGI | Upper Gastrointestinal
Vit D | Vitamin D
WHI | Women's Health Initiative
Zoledr | Zoledronic Acid