# 5 Future Research

Although there is good evidence that a number of the agents reviewed in this report reduce the risk of fracture among postmenopausal women with high risk for fracture, i.e., women with T-scores < -2.5 SD and/or a prior osteoporotic fracture, data on the effect of osteoporosis agents in reducing fracture risk in other populations are limited. Among populations at high risk for fracture, solid-organ and bone marrow transplant recipients comprise a significant and growing population. Further, because the underlying cause of osteoporosis is different than that in postmenopausal women, data on the efficacy of osteoporosis agents in postmenopausal women may not be applicable to this population. Hence, research is needed to determine if/which osteoporosis agents reduce fracture risk among transplant recipients. Among lower risk populations, there are limited data on whether osteoporosis agents reduce the risk of fracture among postmenopausal women with osteopenia and among men. Coupled with good evidence that all osteoporosis agents are associated with side effects that range from mild to serious, further research is needed to determine whether the benefits of treatment in these lower risk populations outweighs the risks. Further, because these groups comprise a large population, results from such studies have the potential to have a large impact ... regardless of the results. Demonstration of fracture risk reduction could lead to broader use of these agents in these populations and reduced fracture rates. Demonstration that fracture risk is not reduced in these populations could lead to the discontinuance of these agents in these populations with a concomitant reduction in adverse events and unnecessary health care spending. A practical challenge in determining whether osteoporosis agents reduce the risk of fracture in lower risk populations is that large sample sizes will be required. Given that the baseline fracture risk is lower and that the time to develop fractures is longer in these lower risk populations, RCTs designed to assess fracture risk would require larger sample sizes and longer follow-up periods than those performed among high-risk postmenopausal women.

Regarding comparative effect of osteoporosis agents on preventing fractures, head-to-head studies of the different agent that have sufficient power to detect differences across study arms are needed. We did not find any studies that assessed the effect of testosterone in men on the development of fractures; fractures could be tracked in large placebo-controlled trials designed to access other outcomes.

Although a number of studies suggested that inconvenient dosing regimens reduced adherence and persistence, we did not identify any studies that specifically assessed the effect of changing dosing regimens on adherence or persistence. Additionally, although studies demonstrate that weekly dosing of osteoporosis medications achieves higher adherence rates than does daily dosing, overall compliance rates are still far below desirable levels. Additional studies will be required to demonstrate whether a change to less frequent medication dosing regimens will improve patient adherence and persistence.

Patients with osteoporosis are more likely to adhere to osteoporosis therapies if they have better understanding of their individual risks for complications of the disease. ^409^ Additionally, patients often do not follow prescribed instructions for taking their medications, and improper medication use may lead to increased side effects. ^294^ Thus, patient education programs may improve adherence to osteoporosis therapy.

Robbins et al. used a patient-education intervention in a cohort of black and Hispanic women who were already participating in a RCT of HRT vs. placebo for osteoporosis. All minority participants received the educational intervention. One year after the educational intervention was implemented, the mean MPR improved significantly in black women from 80% to 88%, and in Hispanic women from 83% to 86%. ^410^ In one other controlled observational study, young postmenopausal women with osteoporosis did not show improvement in adherence rates after receiving an educational leaflet. ^411^ Given these results, more research on patient education, adherence, and outcomes is suggested.

Finally, the recent series of reports of osteonecrosis of the jaw among patients taking bisphosphonates point to the immediate need for epidemiologic research to define whether there is a significant association between bisphosphonates and jaw osteonecrosis, the magnitude of the association and the specific population(s) in which any association exists. Confirmation and definition of such an association could direct the appropriate use of these agents among specific patient populations. Additionally, should such an association be demonstrated, this could direct basic research into possible mechanisms, which might provide insight into the basic pathophysiology of osteoporosis and bone metabolism.