# 4 Summary and Discussion

In this chapter, we describe the limitations of our review and then present our conclusions. We also discuss the implications of our findings for future research.

## Limitations

### Publication Bias

Our literature search procedures were extensive and included canvassing experts from academia and industry for studies. However, it is possible that other unpublished trial results exist for the treatments included in our report. Publication bias may occur, resulting in an overestimation of the efficacy of these treatments.

### Study Quality

An important limitation common to systematic reviews is the quality of the original studies. Recent attempts to assess which elements of study design and execution are related to bias have shown that in many cases, such efforts are not reproducible. Therefore, the current approach is to avoid rejecting studies or using quality criteria to adjust the meta-analysis results. However, we did use as a measure of quality the Jadad scale, which is the only validated set of quality criteria for trials. As there is a lack of empirical evidence regarding other study characteristics and their relationship to bias, we did not attempt to use other criteria.

## Conclusions

With the above limitations in mind, we reached the conclusions displayed in the table below.

Table 68 Summary of evidence

Key Question | Level of Evidence | Conclusion
1. What are the comparative benefits in fracture reduction among and also within the following treatments for low bone density:
a. Bisphosphonates | High | Vertebral fractures: alendronate, etidronate, ibandronate, risedronate and zoledronic acid reduce the risk of vertebral fractures among postmenopausal women with osteoporosis.
| High | Nonvertebral fractures: alendronate, risedronate and zoledronic acid reduce the risk of non-vertebral fractures among postmenopausal women with osteoporosis.
| High | Hip: alendronate, risedronate and zoledronic acid reduce the risk of hip fractures among postmenopausal women with osteoporosis.
| Low | Wrist: alendronate reduces the risk of wrist fractures among postmenopausal women with osteoporosis.
| Low | Based on limited data from head-to-head trials, within the bisphosphonate class, superiority for the prevention of fractures has not been demonstrated for any agent.
| Low | Based on limited data from head-to-head trials, superiority for the prevention of vertebral fractures has not been demonstrated for bisphosphonates in comparison with calcitonin, calcium or raloxifene. However, these studies were not designed or powered to detect fractures.
| Moderate | Based on six RCTs, superiority for the prevention of fractures has not been demonstrated for bisphosphonates in comparison with estrogen.
b. Calcitonin | Moderate | Vertebral fractures: calcitonin reduces the risk of vertebral fractures among postmenopausal women with osteoporosis.
c. Calcium | Moderate | The effect of calcium alone on fracture risk is uncertain. Several large, high quality RCTs were unable to demonstrate a reduction in fracture among postmenopausal women. However, a number of studies have demonstrated that compliance with calcium is low, and a subanalysis in one of the RCTs demonstrated a reduction in fracture risk with calcium relative to placebo among compliant subjects.
d. Estrogen | High | Estrogen reduces the risk of vertebral and hip fractures.
e. PTH (teriparatide) | Moderate/High | Teriparatide is effective in preventing vertebral and non-vertebral fractures.
f. SERMs (raloxifene, tamoxifen) | High | Raloxifene is effective in preventing vertebral fractures.
g. Testosterone | None | There are no data from RCTs to inform this question.
h. Vitamin D | Moderate | The effect of vitamin D on fracture risk is uncertain. Among a number of meta-analyses, some reported a reduced risk for vitamin D relative to placebo, some did not. There was no reduction in fracture risk for vitamin D relative to placebo in a large, high quality RCT published after the meta-analyses.
i. Exercise in comparison to above agents. | None | There are no data from RCTs to inform this question.
2. How does fracture reduction resulting from treatments vary between individuals with different risks for fracture as determined by bone mineral density (borderline/low/severe), prior fractures (prevention vs. treatment), age, gender, glucocorticoid use, and other factors (e.g., community dwelling vs. institutionalized; vitamin D deficient vs. not)? | High | Alendronate, etidronate, ibandronate, risedronate, teriparatide, and raloxifene reduce the risk of fractures among high risk groups including postmenopausal women with osteoporosis.
| Moderate | Calcitonin reduces the risk of fracture among postmenopausal women.
| High | Raloxifene prevents fractures in postmenopausal women at low risk for fracture.
| Low | Teriparatide, risedronate, and calcitonin reduce risk of fracture among men.
| High | Among subjects treated with glucocorticoids, fracture risk reduction was demonstrated for risedronate and alendronate.
| Moderate | Reduction in fracture risk for subjects treated with alendronate, risedronate, or vitamin D has been demonstrated in populations at increased risk for fracture due to conditions that increase the risk of falling including stroke with hemiplegia, Alzheimer's disease, and Parkinson's.
| Low | There are limited and inconclusive data on the effect of agents for the prevention and treatment of osteoporosis on transplant recipients and patients treated with chronic corticosteroids.
3. What are the adherence and persistence to medications for the treatment and prevention of osteoporosis, the factors that affect adherence and persistence, and the effects of adherence and persistence on the risk of fractures? | Moderate | Only 10 RCTs reported rates of adherence to therapy. Five trials of calcium reported high rates of non-adherence. In two studies of daily oral bisphosphonates, more than 80% of patients took at least 70% of the drug. The other three trials reported high rates of adherence with weekly risedronate therapy.
| Moderate | There is evidence from 10 observational studies that adherence to therapy with alendronate, etidronate, risedronate, calcitonin, HRT, raloxifine, and calcium and vitamin D is poor in many postmenopausal women with osteoporosis.
| Low | There is evidence from one observational study that adherence to therapy with alendronate and risedronate is poor in many chronic glucocorticoid users.
| Moderate | There is evidence from 12 observational studies that persistence with therapy with alendronate, etidronate, risedronate, calcitonin, HRT, raloxifene, and calcium and vitamin D is poor in many men and postmenopausal women with osteoporosis.
| Moderate | Based on evidence from observational studies, factors that affect adherence and persistence to medications include side effects of medications, absence of symptoms related to the underlying disease, co-morbid conditions, ethnicity, socioeconomic status, and dosing regimens.
| High | In four observational studies comparing weekly and daily bisphosphonates, weekly users had higher persistence and adherence rates.
| Moderate | There is evidence from RCTs and observational studies that postmenopausal women who are non-adherent to treatment with alendronate, risedronate, HRT, calcium, or calcitonin have an increased risk of fracture compared with women who are adherent to therapy.
| Low | There is evidence from one observational study that postmenopausal women with osteoporosis who are non-persistent with alendronate and risedronate therapy have an increased risk of fracture compared with women persistent with these medications.
4. What are the short- and long-term harms (adverse effects) of the above therapies, and do these vary by any specific subpopulations? | High | There were no differences among bisphosphonates, calcium, vitamin D, calcitonin, PTH, and placebo regarding serious cardiac events.
| High | Zoledronic acid is associated with an increased risk of atrial fibrillation relative to placebo.
| High | Estrogen and estrogen-progestin combination participants had higher odds of cerebrovascular accident (CVA) and thromboembolic events than did placebo participants.
| High | Participants who took raloxifene or tamoxifen showed higher odds for pulmonary embolism than did participants who took a placebo. Raloxifene participants also had greater odds of thromboembolic events.
| Moderate | Esophageal ulcerations were reported in trials of all the bisphosphonates except zoledronic acid. The only significant difference from placebo was found in one trial in which etidronate participants had higher odds of esophageal ulcers.
| Moderate | Perforations, ulcerations (non-esophageal), and bleeds (PUBs) were reported in trials of all the bisphosphonates except zoledronic acid. Etidronate participants had higher odds of PUBs than did placebo patients. Patients taking oral daily ibandronate had lower odds of PUBs than did those taking placebo. Differences between other bisphosphonates and placebo were not statistically significant in pooled analyses.
| Moderate | We categorized conditions such as acid reflux, esophageal irritation, nausea, vomiting, and heartburn as “mild upper GI events.” Etidronate and pamidronate users had greater odds of these events than did placebo participants. Our pooled analyses found no difference between alendronate, ibandronate, risedronate, or zoledronic acid and placebo regarding mild upper GI events. In contrast, alendronate participants had higher odds of mild upper GI events than did etidronate participants in pooled head-to-head trials. Alendronate participants also had higher odds of mild upper GI events in head-to-head trials vs. calcitonin and head-to-head trials vs. estrogen. Etidronate participants had higher odds of mild upper GI events in head-to-head trials vs. estrogen.
| Moderate | In five pooled trials of estrogen vs. placebo, estrogen participants had lower odds of breast cancer. Conversely, in three pooled studies of estrogen-progestin combination vs. placebo, treatment participants had higher odds of breast cancer. One estrogen-progestin study showed that treated participants had lower odds of colon cancer than did placebo participants.
| Low | Osteosarcoma was reported in only one study, a head-to-head trial of raloxifene vs. tamoxifen; differences between groups were not significant.
| Low | We found 41 published cases of osteonecrosis of the jaw in patients taking bisphosphonates. Cases involved pamidronate, zoledronic acid, and alendronate. The vast majority of cases were found in cancer patients taking the medications intravenously.

## Discussion

This report provides a comprehensive summary of the meta-analyses and RCTs that have evaluated the effect of various agents on fracture risk. Consistent with FDA requirements to demonstrate a reduced fracture risk in order to obtain approval of an agent for the treatment of osteoporosis, a number of RCTs have been performed that used fracture as the primary outcome and that were powered to detect a difference in fracture risk among postmenopausal osteoporotic women at high risk for fracture. Across these studies there is a high level of evidence that alendronate, etidronate, ibandronate, risedronate, calcitonin, teriparatide, and raloxifene prevent vertebral and/or nonvertebral (total, hip and/or wrist) fractures in this population. Each of these agents, with the exception of etidronate, has been approved by the FDA for the treatment of osteoporosis. Also, consistent with FDA requirements to obtain approval for the prevention of osteoporosis, i.e., demonstration of an improvement in BMD, not fracture risk reduction, there have been few studies performed that assessed fracture as a primary outcome and had sufficient sample size to detect a difference in fracture risk among subjects at lower risk for fracture. A meta-analysis report that raloxifene ^55^ reduces the risk of vertebral fractures in low-risk populations; one study demonstrated a reduction in the risk of any fracture for ibandronate relative to placebo. ^104^ Each of these agents has been approved by the FDA for the prevention of osteoporotic fractures.

Estrogen is likewise approved by the FDA for the prevention of osteoporotic fractures in postmenopausal women. However, data on fracture risk reduction for estrogen are more complex. The data describing the effect of estrogen on fracture risk suggest that estrogen reduces the risk of vertebral and hip fracture; the effect of estrogen on non-vertebral fractures is less clear. Among three meta-analyses that assessed the risk of vertebral fracture in postmenopausal women, the pooled sample size in one was too small to detect differences in fracture risk across arms. ^47^ The one with the largest pooled sample size (6,723) demonstrated a reduced fracture risk relative to placebo (OR 0.45, 95% CI, 0.45, 0.98) ^53^ and the other ^54^ with a large sample size demonstrated a risk reduction that was nearly statistically significant. (OR 0.68, 95% CI 0.41, 1.07) Likewise, data on the risk for hip fracture demonstrate a significantly reduced risk in the WHI, a large, high quality RCT, ^164^ and a nearly significant risk reduction in a meta-analysis ^47^ that included data from the WHI. Among the three meta-analyses that evaluated the risk of non-vertebral fractures, all reported point estimates for reduced risk, but the 95% confidence intervals varied in relation to sample size. The analysis with the largest sample size (8,774) ^162^ had the narrowest confidence interval and it did not cross null. The other two had smaller sample sizes (7,316 ^47^ and 5,383 ^54^ ) and wider confidence intervals that crossed null.

Tamoxifen and testosterone are not approved by the FDA for the treatment or prevention of osteoporosis. Consistent with this fact, we did not identify any evidence that these agents reduce the risk of fractures. For tamoxifen, there is evidence from one large RCT that tamoxifen is not associated with fracture risk reduction. ^204^ We did not identify any studies that assessed the effect of testosterone on fracture. In contrast, though not approved by the FDA for the prevention or treatment of osteoporosis, the effect of zoledronic acid on fractures is under active investigation, likely in preparation for a petition to the FDA for an approved indication for the treatment of osteoporosis. To this end a large RCT that evaluated the effect of zoledronic acid on fracture among post-menopausal women at high risk for fracture was recently published and demonstrated a reduced risk relative to placebo at three years. ^139^

The evidence for fracture risk reduction is less clear for the other agents assessed in this report. For calcium, several large, high quality RCTs ^65,^ ^206,^ ^207^ were unable to demonstrate a reduction in fracture among postmenopausal women. However, a number of studies have demonstrated that compliance with calcium is low, ^63^ – ^65,^ ^206,^ ^207^ and a sub-analysis in one of the RCTs demonstrated a reduction in fracture risk with calcium relative to placebo among subjects who were compliant with therapy. ^206^

Data on the effect of vitamin D on fracture risk are likewise unclear. Among a number of meta-analyses, some reported a reduced risk for vitamin D relative to placebo, ^50,^ ^52,^ ^58,^ ^61^ and some did not. ^47,^ ^50,^ ^51^ There was some overlap between the studies included in the meta-analyses, although each included some unique studies. The finding of a significant reduction in fracture risk was not related to the size of the pooled sample in the meta-analyses. Notably, one meta-analysis reported a reduction in fracture risk for vitamin D relative to placebo for doses ≥ 800 IU per day, but not for 400 IU per day. However, in a large, high quality RCT published after the meta-analyses, no reduction in fracture risk was observed for 1,000 IU vitamin D relative to placebo among ambulatory people ages 70 and older with a history of prior fracture. ^65^ In another RCT published after the meta-analyses, there was a reduction in fracture risk with 1,000 IU vitamin D relative to placebo for postmenopausal women with hemiplegia due to stroke. Together these data do not prove that vitamin D prevents fractures. However, these data do suggest that in high enough doses, vitamin D might prevent fractures in some high-risk populations. That fracture risk reduction was observed among postmenopausal women with hemiplegia suggests that one mechanism through which vitamin D might prevent fractures is by reducing falls. Indeed, vitamin D-treated subjects in this study had a 59% reduction in falls relative to placebo, consistent with the reduction in falls associated with vitamin D that has been reported in other studies. ^408^

We did not identify any studies that demonstrated superiority of any drug over another for the prevention of fractures. However, none of the head-to-head comparisons between agents had large enough sample sizes to detect differences.

This report also evaluated whether fracture risk reduction varies among individuals with different risks for fracture. Special populations identified in the studies include men, populations with increased risk for fractures as a result of medications or diseases that reduce BMD, and people living with conditions that increase the risk of falling. None of the studies that included subjects at low risk for fracture had sample sizes large enough to detect significant risk reductions for the agents assessed.

Few studies assessed the effect of agents to reduce fracture risk among men. Among nine studies that included men, ^65,^ ^92,^ ^123^ – ^125,^ ^140,^ ^142,^ ^195,^ ^196^ three demonstrated a reduction in fracture risk: one for total fractures with teriparatide, ^196^ one for hip fractures with risedronate, ^124^ and one for vertebral fractures with calcitonin. ^142^ Among the remaining studies, only one had sufficient sample size to assess the effect of agents on fracture. ^65^ In this study, which included men and women, there was no reduction in the rate of fractures for calcium relative to placebo; subgroup analyses found no difference in risk among men and women.

Special populations with increased risk for fractures as a result of medications that were identified included patients on long-term glucocorticoids, ^92,^ ^94,^ ^136,^ ^263,^ ^271^ – ^273^ recipients of solid organ transplants, ^107,^ ^110^ – ^112,^ ^114,^ ^143,^ ^213,^ ^261^ and bone marrow transplant recipients. ^113,^ ^256^ Among subjects treated with glucocorticoids, fracture risk reduction was demonstrated for risedronate ^136,^ ^137,^ ^273^ and alendronate. ^272^ Fracture risk reductions were not demonstrated for any other agents. Both risedronate and alendronate are approved by the FDA for the treatment of glucocorticoid-induced osteoporosis.

Populations at increased risk for fracture due to a disease that is associated with low BMD that were identified included those with primary biliary cirrhosis, ^71,^ ^252^ leprosy, ^125^ and inflammatory bowel disease in remission. ^120^ Among these groups, fracture risk reduction relative to placebo was demonstrated only for patients with inflammatory bowel disease treated with risedronate. ^120^ However, none of the other studies was large enough to detect significant differences across study arms.

Populations identified as being at increased risk for fracture due to conditions that increase the risk of falling included those with stroke with hemiplegia, ^119,^ ^124,^ ^214^ Alzheimer's disease, ^118^ , Parkinson's disease in remission, ^72^ and recent hip fracture. ^89^ Across these studies, there were seven comparisons between alendronate, etidronate, risedronate, or vitamin D and placebo; six of these demonstrated significant reductions in fracture risk for the agent relative to placebo.

The data described in this report also demonstrate that adherence to and persistence with medications for osteoporosis is low and suggests that low adherence is associated with less favorable reductions in fracture risk. Of note, among the RCTs identified to assess the effect of agents on fracture risk, 27 studies reported that adherence to therapy was measured, but only 10 of these reported the rates of adherence to therapy. ^63^ – ^65,^ ^127,^ ^128,^ ^206,^ ^207,^ ^262,^ ^282,^ ^283^ Of these 10, only five included an analysis of outcomes that considered adherence to therapy. ^63,^ ^64,^ ^206,^ ^207,^ ^282^ The effect of adherence on fracture risk was variable in these studies. However, among three large observational studies, ^284^ – ^286^ adherence was inversely related to fracture risk. Factors associated with poor adherence include side effects of medications, absence of symptoms for underlying disease (i.e., osteoporosis or osteopenia), comorbid conditions, age, and socioeconomic status.