# 3 Results

We identified 1,794 titles through our electronic library searches, 97 titles through scientific information packets from pharmaceutical companies, 484 titles through reference mining, and three titles through peer reviewers, for a total of 2,378 titles. After reviewing titles and/or abstracts where available, we ordered 1,831 articles and were unable to obtain 10.

Of the 1,821 articles screened, 1,720 were excluded from our efficacy analyses for the reasons detailed in Figure 1. Appendix D contains a list of these excluded studies. Because systematic reviews already existed for alendronate, risedronate, etidronate, raloxifene, calcitonin, PTH, and estrogen, we did not re-analyze trials of these drugs versus placebo in our efficacy analyses. This means that 166 articles on RCTs were excluded from further efficacy analyses. In total, 76 articles reporting on RCTs and 25 meta-analyses were considered for the efficacy analyses.

Figure 1. Literature flow

*articles considered are not mutually exclusive

Our analyses of adverse events included 490 articles, representing 416 randomized controlled trials, 25 other controlled clinical trials, one open-label trial, and 31 observational studies (case control or cohort). Seven articles reporting cases of osteonecrosis among bisphosphonate users were also described.

## Key Question 1. What are the comparative benefits in fracture reduction among and also within the following treatments for low bone density

- Bisphosphonate medications, specifically: alendronate, etidronate, ibandronate, pamidronate, risedronate,and zoledronic acid
- Calcitonin
- Calcium
- Estrogen for women
- Parathyroid hormone (PTH)
- Selective estrogen receptor modulators (SERMs), specifically: raloxifene and tamoxifen
- Testosterone for men
- Vitamin D
- Combinations of above
- Exercise in comparison to above agents

### Key Points

- There is good evidence from RCTs that, compared with placebo, alendronate, etidronate, ibandronate, risedronate, calcitonin, 1–34 PTH, and raloxifene prevent vertebral fractures.
- There is good evidence from RCTs that both risedronate and alendronate prevent both non-vertebral and hip fractures—compared with placebo.
- There is good evidence that zoledronic acid prevents vertebral and nonvertebral fractures, and fair evidence (see addendum to executive summary) that it prevents hip fractures.
- There is evidence from one RCT that 1–34 PTH prevents non-vertebral fractures—compared with placebo.
- There is good evidence that estrogen is associated with a reduced incidence of vertebral, non-vertebral and hip fractures.
- There are no data from RCTs on the effect of testosterone on the prevention of fractures.
- There is evidence from a published meta-analysis and several RCTs that there is no difference between calcium alone and placebo in preventing vertebral, non-vertebral, hip and wrist fractures in postmenopausal women.
- According to a large body of literature, vitamin D had varying results depending on dose, analogs and population. One meta-analysis found that 700 to 800 I.U. daily was necessary to reduce hip and nonvertebral fractures.
- Based on limited data from head-to-head trials, within the bisphosphonate class, superiority for the prevention of fractures has not been demonstrated for any agent.
- Based on limited head-to-head trial data, superiority for the prevention of vertebral fractures has not been demonstrated for bisphosphonates in comparison with calcitonin, calcium, or raloxifene. However, these studies were not designed or powered to detect fractures.
- Based on six head-to-head RCTs, there was no difference in fracture incidence between bisphosphonates and estrogen. However, none of the trials were powered to detect differences in fracture rates.
- There are no data from RCTs on the effect of exercise relative to agents used to treat or prevent osteoporosis on fracture prevention.

### Detailed Analyses

#### Drug vs. placebo comparisons

For nine of the 14 agents for the prevention or treatment of osteoporosis that were reviewed in this report (alendronate, etidronate, risedronate, calcitonin, estrogen, PTH, raloxifene, calcium, vitamin D), we identified 25 meta-analyses that described the effect of the agent relative to placebo on fracture incidence. ^39^ – ^57,^ ^57^ – ^62^ Many RCTs not included in the meta-analyses described the risk of fracture for these single agents relative to placebo. For four of the five agents for which we did not identify meta-analses (ibandronte, pamidronate, zoledronic acid, tamoxifen) we identified 15 RCTs that described the risk of fracture relative to placebo. We did not find any meta-analyses or RCTs that reported fracture rates for testosterone relative to placebo. For the only agent combination evaluated for this report, i.e., calcium plus vitamin D, we identified three RCTs that evaluated the risk of fracture for combined calium and vitamin D relative to placebo. ^63^ – ^65^

Figures 2 –9 and the following text summarize from the available data the risk (relative to placebo) of developing fracture while taking the agents in question.

Figure 2. Risk of vertebral fracture relative to placebo for subjects at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 3. Risk of vertebral fracture relative to placebo for subjects at not at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 4. Risk of non-vertebral fracture relative to placebo for subjects at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 5. Risk of non-vertebral fracture relative to placebo for subjects at not at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 6. Risk of hip fracture relative to placebo for subjects at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 7. Risk of hip fracture relative to placebo for subjects not at high risk for fracture, by agent*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 8. Pooled risk of wrist fracture among populations at high risk for fracture for agents used to treat or prevent osteoporosis relative to placebo*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

Figure 9. Pooled risk of wrist fracture among populations not defined as at high risk for fracture for agents used to treat or prevent osteoporosis relative to placebo*

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. † Pooled risk estimate from cited meta-analys(is)(es) or systematic review(s). ‡ Pooled risk estimate calculated by authors; restricted to studies with > 12 months of follow-up. § Risk estimate calculated from cited individual study. ** Insufficient data to calculate risk.

#### Bisphosphonates

##### Alendronate

We identified seven meta-analyses ^39,^ ^40,^ ^43,^ ^47,^ ^56,^ ^57,^ ^62^ that pooled data from 17 different RCTs to estimate the effect of alendronate on fracture risk reduction relative to placebo (or no treatment) among postmenopausal women. The studies that were included in each of the meta-analyses are detailed in Table 2. These meta-analyses reported pooled risk estimates for vertebral, non-vertebral, hip, and wrist fractures (Table 3).

Table 2 Randomized controlled trials included in meta-analyses of effect of alendronate on fracture relative to placebo or no treatment, by fracture type*

| Meta-analysis (Author, year)
RCTs (Author, year) | Cranney, 2002 ^39^ | | | | Karpf, 1997 ^40^ | | | Papapoulos, 2004 ^43^ | Stevenson, 2005 ^47^ | | | | Boonen, 2005 ^62^ | Nguyen, 2006 ^56^ | Sawka, 2005 ^57^
| Fracture type*
| V | NV | H | W | NV | H | W | H | V | NV | H | W | NV | H | V | NV
Adami, 1995 ^73^ | X | X | | | X | X | X
Black, 1996 ^74^ | X | X | X | X | | | | X | X | X | X | X | X | X
Bone, 1997 ^75^ | X | X
Bonnick, 1998 ^76^ | | X | | | | | | X | | | | | | X
Chesnut, 1995 ^77^ | X | X | | | X | X | X
Cummings, 1998 ^78^ | X | X | | | | | | X | X | | X | X | X | X
Dursun, 2001 ^79^ | | | | | | | | | X
Greenspan, 1998 ^80^ | | | | | | | | X
Greenspan, 2002 ^81^ | | | | | | | | | | | | | | X
Hosking, 1998 ^82^ | X | X
Liberman, 1995 ^83^ | X | X | | | X | X | X | X | X | X | X | X | X | X
McClung, 1998 ^84^ | X | X
Orwoll, 2000 ^85^ | | | | | | | | | | | | | | | X | X
Pols, 1999 ^86^ | | X | | | | | | | | X | | | | X
Ringe, 2004 ^87^ | | | | | | | | | | | | | | | X | X
Unpublished data | | | | | X | X | X
Weinstein, 1994 ^88^ | | | | | X | X | X

* V=vertebral, NV=non-vertebral, H=hip, W=wrist/forearm; X= Included in pooled analysis.

Table 3 Pooled risk estimates of fracture for alendronate, relative to placebo or no treatment, among postmenopausal women*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral
Cranney, 2002 ^39^
Prevention trials, dose ≥ 5 mg/d | 2 | 1,355 | 0.45 | (0.06, 3.15)
Treatment trials, dose ≥ 5 mg/d | 7 | 8,005 | 0.53 | (0.43, 0.65)
Sawka, 2005 ^57^ | | 375 | 0.36 | (0.17, 0.77)
Stevenson, 2005 ^47^
Subjects with osteoporosis or osteopenia | 3 | 5,093 | 0.60 | (0.46, 0.80)
Subjects with osteoporosis or severe osteoporosis | 2 | 2,827 | 0.53 | (0.42, 0.67)
Non-vertebral
Boonen, 2005 ^62^ | 3 | 7,453 | 0.86 | (0.76, 0.97)
Cranney, 2002 ^39^
All trials, 5 mg/d | 8 | 8,603 | 0.87 | (0.73, 1.02)
All trials, 10–40 mg/d | 6 | 3,723 | 0.51 | (0.38, 0.69)
Treatment trials, 10–40 mg/d | | | 0.51 | (0.38, 0.69)
Karpf, 1997 ^40^ | 5 | 1,602 | 0.71 | (0.50, 1.00)
Sawka, 2005 ^57^ | 2 | 375 | 0.73 | (0.32, 1.67)
Stevenson, 2005 ^47^
Subjects with osteoporosis or osteopenia | 3 | 6,626 | 0.74 | (0.52, 1.06)
Subjects with osteoporosis or severe osteoporosis | 2 | 3,021 | 0.81 | (0.66, 0.98)
Hip
Cranney, 2002 ^39^
All trials, 5 mg/d | 8 | 8,603 | 0.70 | (0.46, 1.05)
All trials, 10–40 mg/d | 6 | 3,723 | 0.45 | (0.18, 1.13)
All trials, 5–40 mg/d | 11 | 11,808 | 0.63 | (0.43, 0.92)
Karpf, 1997 ^40^ | 5 | 1,602 | 0.46 | (0.15, 1.36)
Nguyen, 2005 ^56^ | 6 | 10389 | 0.55 | (0.27, 1.12)
Papapoulos, 2004 ^43^
Subjects with T score ≤ 2.0 or with vertebral fracture | 6 | 9,023 | 0.55 | (0.36, 0.84)
Subjects with T score ≤ 2.5 or with vertebral fracture | 6 | 6,804 | 0.45 | (0.28, 0.71)
Stevenson, 2005 ^47^
Subjects with osteoporosis or osteopenia | 2 | 5,426 | 0.68 | (0.30, 1.54)
Subjects with osteoporosis or severe osteoporosis | 2 | 3,021 | 0.46 | (0.23, 0.91)
Forearm/Wrist
Cranney, 2002 ^39^
All trials, 5 mg/d | 8 | 8,603 | 0.84 | (0.51, 1.40)
All trials, 10–40 mg/d | 6 | 3,723 | 0.48 | (0.29, 0.78)
Karpf, 1997 ^40^ | 5 | 1,602 | 0.39 | (0.19, 0.78)
Stevenson, 2005 ^47^
Subjects with osteoporosis or osteopenia | 2 | 5,426 | 0.67 | (0.19, 2.32)
Subjects with osteoporosis or established osteoporosis | 2 | 3,071 | 0.48 | (0.31, 0.75)

* Cranney: ‘treatment trial’ population has T-score < -2 SD and/or baseline prevalence of fracture is >20% and/or average age is >62; ‘prevention trial’ population has T-score ≥ -2 SD and/or baseline prevalence of fracture is ≤20% and/or average age is ≤62.

Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

We identified seven RCTs ^66^ – ^72^ not included in the meta-analyses that describe the number of fractures among subjects treated with alendronate and placebo (Table 4). The study population in six of these studies was postmenopausal women with intermediate ^67,^ ^69,^ ^70,^ ^72^ or high ^66,^ ^68^ risk for fracture. In one of these studies, the postmenopausal women also had Parkinson's disease. ^72^ The population in the other study comprised men and women with primary biliary cirrhosis, who had an intermediate risk for fracture. ^71^

Table 4 Risk of fracture for alendronate, any dose, relative to placebo, by fracture group

Author, year | Study duration | Type of fracture | Risk level* | Number of fractures, alendronate | Number of fractures, placebo | Odds ratio (95% CI)
TOTAL FRACTURES
Bone, 2000 ^66^ | 24 months | any clinical fracture | High | 5/92 | 4/50 | 0.65 (0.16, 2.66)
Greenspan, 2003 ^67^ | 36 months | clinical fracture | Intermediate | 7/93 | 9/93 | 0.76 (0.27, 2.12)
Hosking, 2003 ^68^ | 12 months | clinically diagnosed vertebral or nonvertebral | High | 6/172 | 2/89 | 1.52 (0.34, 6.67)
VERTEBRAL FRACTURES
McClung, 2006 ^69^ | 12 months | clinical vertebral fracture | Intermediate | 1/46 | 1/46 | 1.00 (0.06, 16.23)
Quandt, 2005 ^70^ | 54 months | clinical vertebral fracture | Intermediate | 12/1878 | 29/1859 | 0.43 (0.23, 0.79)
Zein, 2005 ^71^ | 12 months | new compression/vertebral fracture | Intermediate | 1/14 | 0/13 | 6.88 (0.14, 347.7)
NON-VERTEBRAL FRACTURES
Zein, 2005 ^71^ | 12 months | peripheral fracture | Intermediate | 0/14 | 1/13 | 0.13 (0.00, 6.33)
HIP
Sato, 2006 ^72^ | 48 months | hip fracture | Intermediate | 4/131 | 14/129 | 0.30 (0.12, 0.78)
WRIST
McClung, 2006 ^69^ | 12 months | Radius, ulna, or both | Intermediate | 0/46 | 0/46 | NC
HUMERUS
McClung, 2006 ^69^ | 12 months | Humerus | Intermediate | 0/46 | 0/46 | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

NC=not calculable.

Fracture prevention was the primary outcome in one study, which assessed the effect of alendronate on fracture risk among postmenopausal women at intermediate risk for fracture. ^70^ The risk for vertebral fracture for women treated with alendronate relative to placebo was 0.43 (95% CI 0.23, 0.79). The risk of fracture was significantly lower for alendronate compared with placebo in one other study, which assessed risk among postmenopausal women with Parkinson's disease. ^72^ In this study, fracture was a secondary outcome. The risk of hip fracture for women treated with alendronate relative to placebo was 0.30 (95% CI, 0.12, 0.78).

The risk of fracture was not significantly different between alendronate and placebo in any of the other studies. However, in all other studies, fractures were assessed either as secondary outcomes ^67,^ ^71^ or adverse events. ^66,^ ^68,^ ^69^ The sample sizes in these studies were not sufficiently large to detect differences in fracture risk among study groups.

##### Etidronate

We identified three meta-analyses ^41,^ ^47,^ ^56^ that pooled data from 11 different RCTs to estimate the effect of etidronate on fracture risk reduction relative to placebo or no treatment among postmenopausal women (Table 5). These meta-analyses reported pooled risk estimates for vertebral, non-vertebral, hip, and wrist fractures (Table 6).

Table 5 Randomized controlled trials included in meta-analyses of effect of etidronate on fracture relative to placebo or no treatment

| Meta-analyses (Author, year)
RCTs (Author, year) | Cranney, 2001 ^41^ | | | Stevenson, 2005 ^47^ | | | Nguyen, 2006 ^56^
| Fracture type*
| V | NV | H | V | NV | H | H
Harris, 1995* | | | | | | | X
Herd, 1997 ^95^ | X
Iwamoto, 2001 ^96^ | | | | | X
Lyritis, 1997 ^97^ | X | X | X | X | X | X
Meunier, 1997 ^98^ | X | X
Montessori, 1997 ^99^ | X | X
Pacifici, 1988 ^100^ | X
Pouilles, 1997 ^101^ | X | X
Storm, 1990 ^102^ | X | X | X | | X | | X
Watts, 1990 ^103^ | X | X | X | X | X | X
Wilmalawansa, 1998 ^91^ | X | X | | | X

* V=vertebral, NV=nonvertebral, H=hip, W=wrist/forearm; X= Included in pooled analysis.

Table 6 Pooled risk estimates of fracture for etidronate, relative to placebo or no treatment, among postmenopausal women*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Cranney, 2001 ^41^
All trials | 10 | 1,076 | 0.60 | (0.41, 0.88)
Prevention trials | 5 | 738 | 0.61 | (0.29, 1.26)
Treatment trials | 5 | 338 | 0.59 | (0.38, 0.94)
Stevenson, 2005 ^47^
Subjects with established osteoporosis | 2 | 263 | 0.43 | (0.20, 0.91)
Non-vertebral
Cranney, 2001 ^41^
All trials | 8 | 867 | 0.98 | (0.68, 1.42)
Prevention trials | 4 | 586 | 1.05 | (0.69, 1.60)
Treatment trials | 4 | 281 | 0.75 | (0.34, 1.70)
Stevenson, 2005 ^47^
Subjects with established osteoporosis | 4 | 410 | 1.04 | (0.64, 1.69)
Hip
Cranney, 2001 ^41^
All trials | 4 | 589 | 1.20 | (0.37, 3.88)
Nguyen, 2006 ^56^ | 2 | 489 | 0.38 | (0.004–171.8)
Stevenson, 2005 ^47^
Subjects with severe osteoporosis | 1 | 309 | 0.50 | (0.05, 5.34)

* Cranney: ‘treatment trial’ population has T-score < -2 SD and/or baseline prevalence of fracture is >20% and/or average age is >62; ‘prevention trial’ population has T-score ≥ -2 SD and/or baseline prevalence of fracture is ≤20% and/or average age is ≤62.

Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

We identified six RCTs ^89^ – ^94^ not included in the meta-analyses that describe the number of fractures among subjects treated with etidronate and placebo (Table 7). The study population in three of these studies was postmenopausal women with high ^89,^ ^91,^ ^93^ risk for fracture. The populations in the other three studies were at intermediate risk for fracture and included men and women with asthma ^92^ or connective tissue disease ^94^ requiring treatment with glucocorticoids or amyotrophic lateral sclerosis (ALS). ^90^

Table 7 Risk of fracture for etidronate, any dose, relative to placebo or control, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, etidronate | Number of fractures, placebo or control† | Odds ratio (95% CI)
VERTEBRAL FRACTURES
Campbell, 2004 ^92^ | 60 months | new symptomatic or semi-quantative vertebral fractures | Intermediate | 13/81 | 19/95† | 0.77 (0.36, 1.65)
Ishida, 2004 ^93^ | 24 months | vertebral | High | 8/66 | 17/66† | 0.41 (0.17, 0.99)
Sato, 2003 ^94^ | 36 months | New vertebral | Intermediate | 0/30 | 2/31 | 0.14 (0.01, 2.21)
Sato, 2006 ^90^ | 24 months | vertebral | Intermediate | 0/41 | 3/41 | 0.13 (0.01, 1.27)
Wimalawansa, 1998 ^91^ | 48 months | vertebral | High | 3/14 | 5/14† | 0.51 (0.10, 2.55)
NON-VERTEBRAL FRACTURES
Wimalawansa, 1998 ^91^ | 48 months | nonvertebral | High | 1/14 | 1/14 | 1.00 (0.06, 16.85)
HIP
Sato, 2004 ^89^ | 3 months | hip fracture | High | 0/36 | 0/37 | NC
HUMERUS
Sato, 2006 ^90^ | 24 months | proximal humerus fracture | Intermediate | 1/41 | 1/41 | 1.00 (0.06, 16.27)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† Versus control.

Although fracture was the primary outcome at the start of one study, ^92^ enrollment was lower than anticipated and the final sample size was not sufficiently large to detect differences in fracture risk between etidronate and placebo. In another study, ^90^ the primary and secondary outcomes were not clearly stated, although this study likewise had insufficient sample size to detect differences in fracture risk between etidronate and placebo. In all other studies, fractures were assessed either as secondary outcomes ^91,^ ^93,^ ^94^ or adverse events. ^89^ The sample sizes in these studies were not sufficiently large to detect differences in fracture risk among study groups.

Among all of these studies, the risk of fracture for etidronate relative to placebo was significant in one. ^93^ In this study, which assessed the risk of vertebral fracture among postmenopausal women at high risk for fracture, the risk of fracture for etidronate relative to placebo was 0.41 (95% CI, 0.17, 0.99).

##### Ibandronate

We identified four RCTs ^104^ – ^107^ that reported the effects of ibandronate relative to placebo or control on the incidence of fractures (Table 8). The study population in three of these studies was postmenopausal women with osteoporosis or osteopenia. ^104^ – ^106^ The study population in the other study was male and female kidney transplant recipients. ^107^ In two of these studies, fracture prevention was the primary outcome and the studies had sufficiently large sample sizes to detect differences in fracture risk among study groups. ^105,^ ^106^ In the other two studies, ^104,^ ^107,^ ^108^ fracture data were reported as adverse events among samples not large enough to detect differences in fracture rates among study groups.

Table 8 Risk of fracture for ibandronate, any dose, relative to placebo, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, ibandronate | Number of fractures, placebo | Odds ratio (95% CI)
ALL FRACTURES
Ravn, 1996 ^104^ | 12 months | fracture | Intermediate | 0/150† | 1/30 | 0.002 (0.00, 0.477)
VERTEBRAL
Chesnut, 2004 ^105^ | 36 months | clinical vertebral | High | 44/1954‡ | 41/975 | 0.50 (0.32, 0.79)
Grotz, 2001 ^107^ | 12 months | vertebral | High | 1/40 | 1/40 | 1.00 (0.006, 16.27)
Recker, 2004 ^106^ | 36 months | morphometric vertebral fractures | High | 80/961 | 95/949 | 0.82 (0.60, 1.11)
NON-VERTEBRAL
Chesnut, 2004 ^105^ | 36 months | clinical osteoporotic nonvertebral | High | 176/1954† | 89/975 | 0.995 (0.76, 1.30)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† 0.25mg, 0.50mg, 1.0mg, 2.5mg and 5.0 mg dose groups combined.

‡ daily and intermittent dose groups combined.

Among the studies that evaluated fracture risk as a primary outcome, one assessed the effect of daily and intermittent ibandronate on vertebral (primary outcome) and non-vertebral (secondary outcome) fractures among 1,952 subjects. ^105^ In this study, the risks of clinical vertebral fractures for daily and intermittent ibandronate relative to placebo were the same, 0.54 (95% CI, 0.32, 0.88). The relative risks of clinical non-vertebral fractures for daily and intermittent ibandronate relative to placebo were 1.0 (95% CI, 0.73, 1.36) and 1.09 (95% CI, 0.80, 1.50), respectively. The other study found no association between ibandronate and morphometric vertebral fractures among 2,862 subjects. ^106^

Among the studies that reported fracture data as secondary outcomes ^107^ or adverse events ^104^ , one was performed among 180 postmenopausal women ^104^ and the other among 80 kidney transplant recipients. ^107^ The first of these studies included 5 different dosage groups for ibandronate. Fracture risk for ibandronate relative to placebo was not statistically significant for any individual dose group. However, when all dose groups were pooled, the risk of fracture for ibandronate relative to placebo was slightly but significantly reduced (Table 8). The data reported in these studies did not demonstrate an association between ibandronate and either armor vertebral fractures, but the studies were not powered to do so.

Among the four studies that reported rates of vertebral fractures, the pooled risk of fracture for ibandronate relative to placebo was 0.70 (95% CI 0.54, 0.91).

##### Pamidronate

We identified six RCTs ^109^ – ^114^ that reported the effects of pamidronate relative to placebo or control on the incidence of fractures (Table 9). Four of these studies were performed among male and female organ transplant recipients, ^110,^ ^111,^ ^113,^ ^114^ one among men or women receiving chemotherapy for lymphoma ^109^ and one among postmenopausal women with osteoporosis or osteopenia. ^112^ The occurrence of new fractures was a secondary outcome in all of the studies. These studies reported the following types of fractures: hip, long bone, non-vertebral and vertebral. In the one study that assessed hip fractures, none occurred in either the pamidronate or control groups. ^114^ Relative to control, there was no significant association between pamidronate and long bone fractures (OR 0.48, 95% CI 0.11, 2.17). Likewise, relative to placebo, there was no significant association between pamidronate and non-vertebral fractures (OR 1.21, 95% CI 0.07, 19.96). However, none of the studies had sample sizes large enough to detect a difference in fracture rates between groups.

Table 9 Risk of fracture for pamidronate, any dose, relative to placebo, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, pamidronate | Number of fractures, placebo or control† | Odds ratio (95% CI)
VERTEBRAL
Aris, 2000 ^111^ | 24 months | Vertebral | High | 3/16 | 1/18† | 3.43 (0.44, 26.92)
Coco, 2003 ^114^ | 12 months | Vertebral | High | 1/31 | 2/28† | 0.45 (0.04, 4.52)
Kananen, 2005 ^113^ | 12 months | Vertebral | High | 3/33 | 5/33† | 0.57 (0.13, 2.48)
Kim, 2004 ^109^ | 12 months | vertebral | High | 1/25 | 6/20† | 0.14 (0.03, 0.72)
Ninkovic, 2002 ^110^ | 12 months | vertebral | High | 3/34 | 1/41 | 3.48 (0.47, 25.98)
Reid, 1994 ^112^ | 24 months | vertebral | High | 7/26 | 10/22 | 0.45 (0.14, 1.46)
NONVERTEBRAL
Aris, 2000 ^111^ | 24 months | long bone fracture | High | 3/16 | 6/18† | 0.48 (0.11, 2.17)
Ninkovic, 2002 ^110^ | 12 months | nonvertebral | High | 1/34 | 1/41 | 1.21 (0.07, 19.96)
HIP
Coco, 2003 ^114^ | 12 months | hip fractures | High | 0/31 | 0/28† | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† Control group.

There were sufficient data to perform a pooled analysis only of vertebral fractures. Among the four studies with a 12-month study duration, ^109,^ ^110,^ ^113,^ ^114^ the pooled odds of vertebral fractures for pamidronate relative to placebo or control among 269 subjects was 0.52 (95% CI, 0.21, 1.24). However, this pooled sample size is not large enough to detect a difference in fracture rates between study groups (Table 9 and Figure 11). There are no data on use of pamidronate for postmenopausal osteoporosis.

Figure 11. Pooled risk of vertebral fractures for pamidronate relative to placebo or control among subjects with organ transplants or undergoing chemotherapy

##### Risedronate

We identified five meta-analyses ^44,^ ^47,^ ^56,^ ^60,^ ^62^ that pooled data from 10 different RCTs to describe the effect of risedronate on fracture risk reduction relative to placebo or no treatment, among postmenopausal women. We also identified two manuscripts each that pooled results from two RCTs, one which evaluated post-menopausal women, ^115^ and which evaluated men and women treated with corticosteroids. ^116^ The pooled analysis among post-menopausal women ^115^ is described in this section; the pooled analysis among subjects treated with glucocorticoids ^116^ is described in the section on glucocorticoids in this report (Table 57). The studies that were included in each of the meta-analyses and the pooled analysis among post-menopausal women are detailed in Table 10. The meta-analyses analyses reported pooled risk estimates for vertebral, non-vertebral, hip, and wrist fractures (Table 11). The pooled analysis reported a 47% (95% CI 23% to 63%) and 62% (95% CI 44%, 75%) risk reduction in vertebral fractures for risidronate relative to placebo after one year for doses of 2.5 mg/d and 5.0 mg/d of risedronate, respectively.

Table 10 Randomized controlled trials included in meta-analyses of effect of risedronate on fracture relative to placebo or no treatment

| Meta-analyses (Author, year)
RCTs (Author, year) | Cranney, 2002 ^44^ | | Stevenson, 2005 ^47^ | | | | Boonen, 2005 ^62^ | Miller, 2005 ^60^ | Nguyen, 2006 ^56^ | Watts, 2003 ^115^ | Wallach, 2000 ^116^
| Fracture Type
| Vertebral | Non-vertebral | Vertebral | Non-vertebral | Hip | Wrist | Non-vertebral | Vertebral | Hip | Vertebral | Vertebral
Clemmensen, 1997 ^129^ | X | X
Fogelman, 2000 ^130^ | X | X | | | | | | X
Harris, 1999 ^131^ | X | X | X | X | X | X | X | X | X | X
Hooper, 2005 ^121^ | | | | | | | | X
McClung, 1998 ^132^ * | | X | | | | | | X
McClung 1998 ^132^ *
McClung, 2001 ^133^ * | | X | | | X | | | X
McClung, 2001 ^133^ * | | X | | | | | X | X | X
Mortensen, 1998 ^134^ | X | X
Reginster, 2000 ^135^ | X | X | X | X | X | X | X | X | X | X
Reid, 2000 ^136^ | | | | | | | | | | | X
Cohen, 1999 ^137^ | | | | | | | | | | | X

X= Included in pooled analysis.

* Same study reported in two different abstracts.

** This study combines data from two RCTs, one of which is the study by Cohen ^137^ included in the sytematic review.

Table 11 Pooled risk estimates of fracture for risedronate, relative to placebo or no treatment, among postmenopausal women*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral
Cranney, 2002 ^44^ | 5 | 2,604 | 0.64 | (0.54, 0.77)
Miller, 2005 ^60^
Subjects with severe renal impairment | 9 | 232 | 0.56 | (0.11, 0.78)
Subjects with moderate renal impairment | 9 | 2426 | 0.45 | (0.31, 0.57)
Subjects with mild renal impairment | 9 | 3088 | 0.32 | (0.14, 0.46)
Stevenson, 2005 ^47^ | 2 | 2,064 | 0.62 | (0.50, 0.77)
Non-vertebral
Boonen, 2005 ^62^ | 3 | 11,770 | 0.81 | (0.71, 0.92)
Cranney, 2002 ^44^ | 7 | 12,958 | 0.73 | (0.61, 0.87)
Stevenson, 2005 ^47^ | 2 | 2,439 | 0.67 | (0.50, 0.90)
Hip
Nguyen, 2006 ^56^ | 3 | 7,196 | 0.66 | (0.11, 3.68)
Stevenson, 2005 ^47^
Subjects with established osteoporosis | 3 | 4,142 | 0.60 | (0.42, 0.88)
Subjects with severe osteoporosis or osteoporosis | 3 | 7,884 | 0.66 | (0.48, 0.89)
Wrist
Stevenson, 2005 ^47^
Subjects with severe osteoporosis | 2 | 2,439 | 0.68 | (0.43, 1.08)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

Table 57 RCTs of bisphosphonates used to treat or prevent glucocorticoid-induced osteoporosis that report fracture data included in prior systematic review*

Author, year | Bisphosphonate | Control | N | Mean daily steroid dose | Population | Results
Studies included in systematic review
Adachi, 1997 ^274^ | Cyclical etidronate: 400 mg/d X 2weeks, then 500 mg/d Ca X 11 weeks; could use 1000 u/d vit D | Cyclical placebo, then 500 mg/d Ca; could use 1000 u/d vitamin D | 117 | 11 mg prednisone | Primary; 42 men/75 women | Trend toward reduced fracture risk for etidronate.
| | | | | Mean age 58 years with primarily RA, PMR
Cohen, 1999 ^137^ | Risedronate 2.5 or 5 mg/d + 1000mg/d Ca + 400 u/d vit D | Placebo + 1000 mg/d Ca + 400u/d vit D | 290 | 15 mg prednisone | Secondary, men and women | Trend toward reduced fracture risk for risedronate.
| | | | | Mean age 58.4, primarily RA, PMR
Cortet, 1999 ^281^ | Cyclical etidronate 400 mg/d X 2 weeks then 500 mg/d Ca X 11 weeks | 500 mg/d Ca | 12 | Nr | Primary, 3 men/ 9 women (33% postmenopausal) with primary biliary cirrhosis | Fractures reported but not analyzed.
Geusens, 1998 ^280^ | Cyclical etidronate 400 mg/d X 2 weeks then 500 mg/d Ca X 11 weeks; could use 1000 u/d vit D | Cyclical placebo, then 500 mg/d Ca; could use 1000 u/d vitamin D | 83 | 12.5 mg prednisone | Primary, 28 men/ 55 women (84% postmenopausal) with primary RA and PMR | No significant difference in fracture rate but not powered to detect.
Jenkins, 1999 ^279^ | Cyclical etidronate 400 mg/d X 2 weeks then 97 mg/d Ca + 400 u/d vit D X 11 weeks | Cyclical placebo then 97 mg/d Ca + 400400 u/d vit D | 49 | 7.5 mg prednisolone | Secondary 19 men/ 30 women, mean age 59 years, with asthma, PMR, and SLE | Fractures reported but not analyzed.
Jensen, 1998 ^277^ | Risedronate | 1000 mg/d Ca | 55 | 8.5 mg prednisone | Unknown combination 11 men/ 44 women (mean age 64) with primarily PMR, TA, asthma | Significant reduction in fracture risk for risedronate relative to placebo.
Roux, 1998 ^275^ | Clodronate 800, 1600, or 2400 mg/d | Placebo | 74 | 8 mg prednisolone | Secondary 33 men/ 41 women (73% postmenopausal) age range 39–73, with asthma or COPD | No significant difference in fracture rate but not powered to detect.
Saag, 1998 ^276^ | Risedronate 2.5, 5, or 10 mg/d + 500 mg/d Ca | Placebo + 500 mg/d Ca | 477 | 21 mg prednisone | Primary 477 men and women (70% postmenopausal) mean age 59.4±14.3, primarily RA, PMR, SLE | Trend toward reduced fracture risk for risedronate.
Skingle, 1999 ^278^ | Cyclical etidronate 400 mg/d X 2 wks then 500 mg/d Ca 11 wks | Cyclical placebo then 500 mg/d Ca | 28 | 9 mg/d prednisolone | Primary 11 men/ 17 women with PMR or RA | Fractures reported but not analyzed.
Studies published after systematic review
Adachi, 2001 ^272^ | Alendronate 5 or 10 mg X 24 mos (or 2.5 mg for 12 mos and 10 mg for 12 mos) + 800–1000 mg/d Ca + 250–500 u/d vit D | Placebo + 800–1000 mg/d Ca + 250–500 u/d vit D | 208 | 7.5 mg prednisone (10 mg in year 2) | 66 men/ 142 women (63% postmenopausal), age range 21–79 | 90% reduction in vertebral fractures (2 years); 70% reduction in nonvertebral fractures.
Reid, 2000 ^136^ | Risedronate 2.5 or 5 mg/d + 1g/d Ca + 400 u/d vit D X 12 mos | Placebo + 1g/d Ca + 400 u/d vit D | 290 | ≥7.5 mg prednisone | Ambulatory men and women, age 18–85, primarily RA, dermatologic, respiratory diseases | 70% reduction in vertebral fractures.
Wallach, 2000 ^273^ | Risedronate 2.5 or 5 mg/d + 1000 mg/d Ca + 400 u/d vit D X 12 mos | Placebo + 1000 mg/d Ca + 400 u/d vit D | 509 | 7.5 mg prednisone equivalent | 184 Men/ 325 women (78% postmenopausal), age range 18–85 years, primarily RA, PMR, TA, CILD, COPD, asthma, and others | 2.5 mg risedronate: 58% reduction in vertebral fractures; 5 mg risedronate: 70% reduction in vertebral fractures.

* Systematic review by Blair et al., 2000 ^271^ ;

CILD Chronic infiltrative lung disease, COPD chronic obstructive pulmonary disease, PMR polymyalgia rheumatica, RA rheumatoid arthritis, SLE Systemic Lupus Erythematosus

We identified ten RCTs ^68,^ ^117^ – ^125^ not included in the meta-analyses that describe the number of fractures among subjects treated with risedronate and placebo (Table 12). The study population in six of these studies was postmenopausal women with high risk for fracture; ^68,^ ^117^ – ^120,^ ^122,^ ^125^ in one it was postmenopausal women with intermediate risk of fracture. ^121^ The populations in the other three studies were male or predominantly male subjects at increased risk for fracture due to stroke, ^124^ leprosy ^125^ or marching (military recruits at risk for stress fractures). ^123^

Table 12 Risk of fracture for risedronate, relative to placebo, by dose and fracture group

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, risedronate | Number of fractures, placebo | Odds ratio (95% CI)
ANY DOSE, ALL FRACTURES
Greenspan, 2006 ^122^ | 12 months | fracture | High | 2/43 | 0/44 | 7.75 (0.48, 125.9)
Hosking, 2003 ^68^ | 12 months | clinically diagnosed vertebral or nonvertebral | High | 6/178 | 2/89 | 1.47 (0.33, 6.52)
Milgrom, 2004 ^123^ | 14 weeks | all stress fracture | Unknown | 24/165 | 21/159 | 1.12 (0.60, 2.10)
2.5 MG DAILY, VERTEBRAL
Hooper, 2005 ^121^ | 24 months | vertebral fracture | High | 11/127 | 10/125 | 1.09 (0.45, 2.66)
Kanaji, 2006 ^125^ | 12 months | vertebral fractures | Intermediate | 0/12 | 0/11 | NC
2.5 MG DAILY, NON-VERTEBRAL
Hooper, 2005 ^121^ | 24 months | nonvertebral fracture | High | 3/127 | 6/127 | 0.5 (0.13, 1.9)
Sato, 2005 ^118^ | 18 months | nonvertebral fracture | High | 8/231 | 29/230 | 0.29 (0.15, 0.57)
2.5 MG DAILY, HIP
Sato, 2005 ^118^ | 18 months | hip fracture | High | 5/231 | 19/230 | 0.29 (0.13, 0.66)
Sato, 2005 ^124^ | 18 months | hip fracture | High | 2/134 | 10/133 | 0.25 (0.08, 0.78)
Sato, 2005 ^119^ | 12 months | hip fracture | High | 1/172 | 7/173 | 0.22 (0.05, 0.88)
5.0 MG DAILY, VERTEBRAL
Sorensen, 2003 ^117^ | 24 months | vertebral fracture | High | 15/109 | 29/103 | 0.42 (0.22, 0.81)
Hooper, 2005 ^121^ | 24 months | vertebral fracture | High | 10/129 | 10/125 | 0.97 (0.39, 2.40)
5.0 MG DAILY, NON-VERTEBRAL
Sorensen, 2003 ^117^ | 24 months | nonvertebral fracture | High | 7/135 | 11/129 | 0.59(0.23, 1.54)
Hooper, 2005 ^121^ | 24 months | non vertebral fracture | High | 5/129 | 6/129 | 0.83 (0.25, 2.76)
5.0 MG DAILY, HUMERUS
Sorensen, 2003 ^117^ | 24 months | humerus | High | 3/136 | 6/130 | 0.48 (0.13, 1.81)
30–35 MG WEEKLY, ALL FRACTURES
Greenspan, 2006 ^122^ | 12 months | fracture | High | 2/43 | 0/44 | 7.75 (0.48, 125.9)
Milgrom, 2004 ^123^ | 14 weeks | all stress fracture | Unknown | 24/165 | 21/159 | 1.12 (0.60, 2.10)
35 MG WEEKLY, VERTEBRAL
Palomba, 2005 ^120^ | 12 months | vertebral fracture | High | 5/40 | 14/41 | 0.30 (0.11, 0.84)
35 MG WEEKLY, NON-VERTEBRAL
Palomba, 2005 ^120^ | 12 months | non-vertebral fracture | High | 0/40 | 4/41 | 0.13 (0.02, 0.95)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

Fracture was the primary outcome in six of the studies. Significant reductions in the risk of vertebral and non-vertebral fractures for risedronate relative to placebo were reported in five of these studies, all of which included populations at high risk for fracture. ^117^ – ^120,^ ^124^ In one of these studies there was a significant reduction in risk for vertebral but not non-vertebral or humeral fractures. ^117^ The study population and fracture risk was unique in the one study for which fracture risk was a primary outcome, but there was no difference in risk between the arms. This study assessed the risk of stress fractures induced by marching in health military recruits with mean age 19 years. ^123^

None of the studies that assessed fracture as secondary outcomes or adverse events demonstrated a significant difference in fracture risk between risedronate and placebo. ^121,^ ^125,^ ^126^ None of these studies has sufficient sample size to detect a difference.

We identified three studies that reported fractures for different doses of risedronate (Table 13). ^126^ – ^128^ The risk of fracture did not differ between dose groups. However, fracture data were collected as secondary outcomes or adverse events in all of these studies and none had sufficient sample size to detect differences between dose groups. Among studies that compared various doses to placebo (but did not have different doses within the same study) and for which fracture was a primary outcome, there were reductions in the risks of all fractures, non-vertebral, and hip fractures with 2.5 mg daily dosing and reductions in the risk of vertebral fractures for 5.0 mg daily and 30 mg weekly dosing.

Table 13 Risk of fracture for risedronate, relative to different doses of risedronate, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, risedronate, weekly | Number of fractures, risedronate, daily | Odds ratio (95% CI)
RISEDRONATE 2.5 MG/D COMPARED TO RISEDRONATE 17.5MG/WEEK
VERTEBRAL
Kishimoto, 2006 ^126^ | 48 weeks | vertebral fracture | Intermediate | 6/222 | 5/227 | 1.23 (0.37, 4.00)
RISEDRONATE 5 MG/D VERSUS RISEDRONATE 35MG/WEEK
VERTEBRAL
Brown, 2002 ^128^ | 24 months | new morphometric vertebral fractures | High | 6/480 | 5/485 | 1.21 (0.37, 3.98)
Harris, 2004 ^127^ | 24 months | morphometric vertebral fractures | High | 12/415 | 7/422 | 1.92 (0.75, 4.88)
NON-VERTEBRAL
Brown, 2002 ^128^ | 24 months | any nonvertebral fractures | High | 24/480 | 28/485 | 0.86 (0.49, 1.50)
RISEDRONATE 5 MG/D VERSUS RISEDRONATE 50MG/WEEK,
VERTEBRAL
Brown, 2002 ^128^ | 24 months | new morphometric vertebral fractures | High | 6/480 | 2/491 | 2.8 (0.7, 11.26)
Harris, 2004 ^127^ | 24 months | morphometric vertebral fractures | High | 12/415 | 7/422 | 1.74 (0.70, 4.32)
NON-VERTEBRAL
Brown, 2002 ^128^ | 24 months | any nonvertebral fractures | High | 24/480 | 24/491 | 1.02 (0.57, 1.83)
RISEDRONATE 35 MG/WEEK VERSUS RISEDRONATE 50MG/WEEK,
VERTEBRAL
Brown, 2002 ^128^ | 24 months | new morphometric vertebral fractures | High | 5/485 | 2/491 | 1.19 (0.68, 2.08)
Harris, 2004 ^127^ | 24 months | morphometric vertebral fractures | High | 12/415 | 7/422 | 0.9 (0.30, 2.68)
NON-VERTEBRAL
Brown, 2002 ^128^ | 24 months | any nonvertebral fractures | High | 28/485 | 24/491 | 1.19 (0.68, 2.08)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, OR 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Zoledronic acid

We identified two RCTs ^138,^ ^139^ that reported the effect of zoledronic acid relative to placebo on the incidence of vertebral and non-vertebral fractures among postmenopausal women at intermediate risk for fracture. In one study 351 postmenopausal women were randomized to different doses and frequencies of zoledronic acid ranging from 1–4 milligrams given in 1–4 doses over a one-year period. Fracture incidence was a secondary outcome in this study. Among 59 subjects randomized to placebo and 292 subjects randomized to zoledronic acid, none sustained vertebral fractures during the 1-year study period. There were five non-vertebral fractures each in the zoledronic acid and placebo groups. There was no significant association between any dose of zoledronic acid and non-vertebral fractures relative to placebo (Table 14). However, this study does not have sufficient statistical power to detect differences in fracture among study arms.

Table 14 Risk of fracture for zoledronic acid, relative to placebo, by dose, frequency, and fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, zoledronic acid | Number of fractures, placebo | Odds ratio (95% CI)
5 MILLIGRAMS ONCE
Black, 2007 ^139^ | 36 months | Any clinical; fracture | High | 308/3667 | 456/3563 | 0.63 (0.54, 0.72)
Black, 2007 ^139^ | 36 months | Nonvertebral fracture | High | 292/3650 | 388/3626 | 0.73 (0.62, 0.85)
Black, 2007 ^139^ | 36 months | Morphometric vertebral fracture | High | 92/2788 | 310/2844 | 0.32 (0.26, 0.39)
Black, 2007 ^139^ | 36 months | Clinical vertebral fracture | High | 19/3800 | 84/3231 | 0.23 (0.16, 0.34)
Black, 2007 ^139^ | 36 months | Hip fracture | High | 52/3714 | 88/3520 | 0.56 (0.40, 0.78)
4 MILLIGRAMS ONCE
Reid, 2002 ^138^ | 12 months | Nonvertebral fracture | Intermediate | 1/60 | 1/59 | 0.98 (0.06, 15.91)
Reid, 2002 ^138^ | 12 months | Vertebral fractures | Intermediate | 0/60 | 0/59 | NC
2 MILLIGRAMS, EVERY 6 MONTHS
Reid, 2002 ^138^ | 12 months | Nonvertebral fracture | Intermediate | 1/61 | 1/59 | 0.97 (0.06, 15.65)
Reid, 2002 ^138^ | 12 months | Vertebral fractures | Intermediate | 0/61 | 0/59 | NC
0.25 MILLIGRAMS, EVERY 3 MONTHS
Reid, 2002 ^138^ | 12 months | Nonvertebral fracture | Intermediate | 0/60 | 1/59 | 0.13 (0.00, 6.71)
Reid, 2002 ^138^ | 12 months | Vertebral fractures | Intermediate | 0/60 | 0/59 | NC
0.5 MILLIGRAMS, EVERY 3 MONTHS
Reid, 2002 ^138^ | 12 months | Nonvertebral fracture | Intermediate | 1/58 | 1/59 | 1.02 (0.06, 16.46)
Reid, 2002 ^138^ | 12 months | Vertebral fractures | Intermediate | 0/58 | 0/59 | NC
1 MILLIGRAM, EVERY 3 MONTHS
Reid, 2002 ^138^ | 12 months | Nonvertebral fracture | Intermediate | 2/53 | 1/59 | 2.2 (0.22, 21.7)
Reid, 2002 ^138^ | 12 months | Vertebral fractures | Intermediate | 0/53 | 0/59 | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population. NC= not calculable.

In the other study, 7,765 postmenopausal women at high risk for fracture were randomized to a single infusion of zoledronic acid at baseline or placebo and followed over three years. ^139^ The primary end points in this study were new vertebral and hip fractures; nonvertebral fractures, any clinical fractures, and clinical vertebral fractures were secondary outcomes. There were significant reductions in the risk of each of these types of fractures for zoledronic acid relative to placebo at 36 months (Table 14).

##### Calcitonin

We identified four meta-analyses ^42,^ ^45,^ ^46,^ ^59^ that describe the effect of calcitonin on fracture risk reduction relative to placebo or no treatment. One focused on the use of calcitonin for the prevention and treatment of glucocorticoid-incuded osteoporosis ^42^ and is described in the section on glucocorticoid-induced osteoporosis in this report. The RCTs included in the remaining three meta-analyses are detailed in Table 15. These meta-analyses reported pooled risk estimates for vertebral and non-vertebral fractures (Table 16). One of the meta-analyses was restricted to postmenopausal women; ^45^ one to renal transplant recipients; ^59^ and the other was not restricted to a specific population and included postmenopausal women, men and women with osteoporosis, as well as men and women taking corticosteroids. ^46^

Table 15 Randomized controlled trials included in meta-analyses of effect of calcitonin on fracture relative to placebo or no treatment

| Meta-analyses (Author, year)
RCTs (Author, year) | Cranney, 2002 ^45^ | | Kanis, 1999 ^46^ | | Palmer, 2005 ^59^
| Fracture Type
| Vertebral | Non-vertebral | Vertebral | Non-vertebral | Any
Arnala, 1996 ^144^ | | | X | X
Agrawal, 1980 ^145^ | | | X | X
Chesnut, 2000 ^146^ | X | X
Gennari, 1985 ^147^ | | | X
Grotz, 1998 ^148^ | | | | | X
Gruber, 1984 ^149^ | | | X
Healey, 1996 ^150^ | | | X
Hizmetli, 1996 ^151^ | X
Luengo, 1994 ^152^ | | | X | X
Nordal, 1996 ^153^ | | | | | X
Overgaard, 1992 ^154^ | X | X | X | X
Peyron, 1980 ^155^ | | | X
Rico, 1992 ^156^ | | | X | X
Rico, 1995 ^157^ | | X | X
Ringe, 1990 ^158^ | | | X | X
Ringe, 1987 ^159^ | | | X | X
Sambrook, 1993 ^160^ | | | X | X
Stock, 1997 ^161^ | | | X

X=Included in pooled analysis.

Table 16 Pooled risk estimates of fracture for calcitonin relative to placebo or no treatment

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral
Cranney, 2002 ^45^ | 4 | 1,404 | 0.46 | (0.25, 0.87)
Kanis, 1999 ^46^ | 10 | 1,744 | 0.80 | (0.64, 1.01)
Non-vertebral
Cranney, 2002 ^45^ | 3 | 1,481 | 0.52 | (0.22, 1.23)
Kanis, 1999 ^46^ | 10 | 1,744 | 0.48 | (0.20, 1.15)
Any Site
Palmer, 2005 ^59^ | 2 | 93 | 0.33 | (0.04, 3.05)

We identified five RCTs ^93,^ ^140^ – ^143^ not included in the meta-analyses that describe the number of fractures among subjects treated with calcitonin and placebo (Table 17). The study population in two of these studies was postmenopausal women with high risk for fracture; ^93,^ ^140^ and in one, it was postmenopausal women with low risk of fracture. ^141^ The population in the fourth study ^142^ was men with osteoporosis at high risk for fracture. The population in the last of these studies was liver transplant recipients. ^143^

Table 17 Risk of fracture for calcitonin, relative to placebo, by dose and fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, calcitonin | Number of fractures, placebo or control† | Odds ratio (95% CI)
100 IU DAILY
Hay, 2001 ^143^ | 12 months | Spine fracture | High | 5/27 | 8/28 | 0.58 (0.17, 1.99)
20 IU WEEKLY
Ishida, 2004 ^93^ | 24 months | vertebral | High | 8/66 | 17/66† | 0.41 (0.17, 0.99)
200 IU DAILY
Trovas, 2002 ^140^ | 12 months | vertebral fracture | High | 1/13 | 2/11 | 0.40 (0.04, 4.30)
200 IU DAILY DURING ALTERNATE MONTHS
Toth, 2005 ^142^ | 18 months | vertebral fracture | High | 0/40 | 3/31† | 0.09 (0.01, 0.96)
10 IU TWICE MONTHLY
Ushiroyama, 2001 ^141^ | 12 months | vertebral fracture | Low | 0/49 | 2/52† | 0.14 (0.01, 2.28)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population. IU = international units

† Versus control group

Fracture was a secondary outcome in all of the studies. Significant reductions in the risk of vertebral fractures for calcitonin relative to placebo were reported in two studies, one among postmenopausal women at high risk for fracture (OR 0.41, 95% CI 0.17, 0.99), ^93^ the other among men with osteoporosis at high risk for fracture (OR 0.09, 95% CI 0.01, 0.96). ^142^ The risk of vertebral fracture for calcitonin relative to placebo was not significant in the other two studies. ^140,^ ^141^

##### Estrogen

We identified four meta-analyses ^47,^ ^53,^ ^54,^ ^162^ and two publications from the Women's Health Initiative (WHI) ^163,^ ^164^ published after the meta-analyses that evaluated the effect of estrogen on fracture risk. The meta-analyses pooled data from 31 different RCTs. The RCTs included in these meta-analyses are detailed in Table 18.

Table 18 Randomized controlled trials included in meta-analyses of effect of estrogen on fracture relative to placebo or no treatment*

| Meta-analyses (Author, year)
RCTs (Author, year) | Stevenson, 2005 ^47^ | | | | Torgerson, 2001 ^53^ | Torgerson, 2001 ^162^ | Wells, 2002 ^54^
| Fracture type†
| V | NV | H | W | V | NV | V | NV
Aitken, 1973 ^167^ | | | | | | X
Alexandersen, 1999 ^168^ | X | X | | | X | X | X | X
Bjarnason, 2000 ^169^ | | X | | | | X
Cauley, 2001 ^170^ | | | X | X
Cheng, 2000 ^171^ | | | | | | X
Delmas, 2000 ^172^ | | X | | | X | X
Eiken, 1997 ^173^ | | X | | | | X
Eli Lily, 2001‡ | | | | | | X
Gallagher, 2001 ^174^ | X | X | | | X
Genant, 1997 ^175^ | | X | | | | X
Greenspan, 1998 ^176^ | | | | | | | X | X
Herrington (HERS), 2000 ^177^ | | X | X | X | X | X
Hosking, 1998 ^82^ | | | | | | X | | X
Hully, 1998 ^178^ | | | | | | X | X | X
Ishida, 2001 ^179^ | | | | | X
Komulainen, 1997 ^180^ | | | | | | | | X
Komulainen, 1998 ^181^ | | | | | | X
Lees, 2001 ^182^ | | X | X | X
Lindsay, 1990 ^183^ | | X | | | X | X
Lufkin, 1992 ^184^ | X | X | | | X | | X
Mosekilde, 2000 ^185^ | X | X | | | X | X
Mulnard, 2000 ^186^ | | | | | | X
Nachtigall, 1979 ^187^ | | | | | | X
Orr-Walker, 2000 ^188^ | | X | | | | X
PEPI, 1996 ^189^ | | | | | X | X
Ravn (EPIC), 1999 ^190^ | | | X | X | X | X
Recker, 1999 ^191^ | | X | | | X | X
Rossouw (WHI), 2002 ^164^ | | | X | X
Stevenson, 2000 ^192^ | | | | | | X
Wimalawamsa, 1998 ^91^ | | X | | | X | X | X | X
Weiss, 1999 ^193^ | | X | | | | X

* HERS= Heart and Estrogen/progestin Study, WHI = Women's Health Initiative.

† V=vertebral, NV=nonvertebral, H=hip, W=wrist/forearm X= Included in pooled analysis.

‡ Citation not provided.

Among three meta-analyses that evaluated risk for vertebral fracture, one demonstrated a statistically significant risk reduction (Table 19). Likewise, among three meta-analyses that evaluated risk for non-vertebral fracture, one demonstrated a statistically significant risk reduction (Table 19).

Table 19 Risk estimates of fracture for estrogen relative to placebo or no treatment among postmenopausal women from pooled analyses and from the Women's Health Initiative*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Torgerson, 2001 ^53^ | 13 | 6,723 | 0.67 | (0.45, 0.98)
Stevenson, 2005 ^47^
Women with severe osteoporosis* | 1 | 68 | 0.58 | (0.26, 1.30)
Women with severe osteoporosis, osteoporosis or osteopenia | 2 | 104 | 0.71 | (0.24, 2.12)
Women not selected for low BMD | 2 | 1,218 | 2.05 | (0.71, 5.97)
Wells, 2002 ^54^ | 5 | 3,385 | 0.66 | (0.41, 1.07)
Women's Health Initiative, 2003 ^165^ Estrogen only | 1 | 10,739 | 0.62† | (0.42, 0.93)
Women's Health Initiative, 2003 ^164^ Estrogen plus progesterone | 1 | 16,608 | 0.66† | (0.44, 0.98)
Non-vertebral
Torgerson, 2001 ^162^
All women | 22 | 8,774 | 0.73 | (0.56, 0.94)
Women < 60 | 14 | ND | 0.67 | (0.46, 0.98)
Women ≥ 60 | 88 | ND | 0.88 | (0.71, 1.08)
Stevenson, 2005 ^47^
Women with severe osteoporosis | 2 | 86 | 0.67 | (0.12, 3.93)
Women with severe osteoporosis, osteoporosis or osteopenia | 4 | 264 | 0.86 | (0.37, 1.96)
Women with osteoporosis or osteopenia | 1 | 128 | 1.17 | (0.41, 3.28)
Women not selected for low BMD | 13 | 7,316 | 0.86 | (0.72, 1.02)
Wells, 2002 ^54^ | 6 | 5,383 | 0.87 | (0.71, 1.08)
Hip
Stevenson, 2005 ^47^
Women not selected for low BMD | 4 | 20,798 | 0.74 | (0.53, 1.03)
Women's Health Initiative, 2003 ^165^ Estrogen only | 1 | 10,739 | 0.61† | (0.41, 0.91)
Women's Health Initiative, 2003 ^164^ Estrogen plus progesterone | 1 | 16,608 | 0.67† | (0.47, 0.96)
Forearm/Wrist
Stevenson, 2005 ^47^
Women not selected for low BMD | 4 | 4,160 | 0.95 | (0.58, 1.53)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD; ND = not described.

† Hazards ratio as reported in cited studies.

Although some data from the WHI are included in one of the meta-analyses ^47^ , the results from this trial are noteworthy. In the estrogen plus progestin component of the WHI, 16,608 postmenopausal women aged 50–79 years were randomized to received conjugated equine estrogens, 0.625 mg/d, plus medroxyprogesterone acetate, 2.5 mg/d, in one tablet or placebo. Estrogen plus medroxyprogesterone was associated with a 33% reduction in vertebral fractures, 33% reduction in hip fractures, and 24% overall reduction in fracture compared with placebo, all of which were statistically significant (Table 19) ^163,^ ^164^ The estrogen alone arm of the WHI also showed a significant reduction in total, vertebral and hipfractures, compared to placebo (Table 19). ^165^ Data on this risk of hip fracture from the estrogen plus progesterone component of WHI were included in the Stevenson meta-analysis; ^47^ data from the estrogen alone component of the WHI and data on vertebral fractures from the WHI were not used to calculate risk estimates in the Stevenson meta-analysis.

We identified five RCTs ^66,^ ^67,^ ^91,^ ^93,^ ^166^ not included in the meta-analyses that describe the number of fractures among subjects treated with estrogen and placebo or control (Table 20). The study population in three of these studies was postmenopausal women with high risk for fracture; ^66,^ ^91,^ ^93^ and in two, it was postmenopausal women with intermediate risk of fracture. ^67,^ ^166^ Data on fracture were collected as secondary in two studies ^91,^ ^93^ or adverse events ^66,^ ^67,^ ^166^ in each of three studies. None of these studies had sufficient sample size to detect a difference in fracture risk between study arms.

Table 20 Risk of fracture for estrogen, relative to placebo, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, estrogen | Number of fractures, placebo or control | Odds ratio (95% CI)
ALL FRACTURES
Bone, 2000 ^66^ | 24 months | any clinical fracture | High | 10/143 | 4/50 | 0.86 (0.25, 2.97)
Greenspan, 2003 ^67^ | 36 months | clinical fracture | Intermediate | 5/93 | 9/93 | 0.54 (0.18, 1.60)
VERTEBRAL
Ishida, 2004 ^93^ | 24 months | vertebral | High | 7/66† | 17/66‡ | 0.36 (0.15, 0.88)
Reid, 2004 ^166^ | 36 months | vertebral | Intermediate | 1/102 | 1/90 | 0.88 (0.05, 14.27)
Wimalawansa, 1998 ^91^ | 48 months | vertebral | High | 2/15† | 5/14‡ | 0.31 (0.06, 1.64)
NONVERTEBRAL
Wimalawansa, 1998 ^91^ | 48 months | Nonvertebral | High | 1/15† | 1/14‡ | 0.93 (0.06, 15.69)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, OR 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† Estrogen plus progesterone.

‡ Control group.

#### 1–34 Parathyroid Hormone

##### Teriparatide

We identified one systematic review ^47^ that summarized data about the effect of teriparatide on fracture relative to placebo or no treatment among postmenopausal women. The RCTs included in this systematic review are detailed in Table 21. This systematic review reported risk estimates for vertebral, non-vertebral, hip, wrist, and humerus fractures (Table 22).

Table 21 Randomized controlled trials included in systematic review of the effect of teriparatide on fracture relative to placebo or no treatment

| Systematic review (Author, year)
RCTs (Author, year) | Stevenson, 2005 ^47^
| Vertebral | Non-vertebral | Hip | Wrist | Humerus
Cosman, 2001 ^197^ | X
Neer, 2001 ^198^ | X | X | X | X | X

Table 22 Pooled risk estimates of fracture for teriparatide relative to placebo or no treatment among postmenopausal women*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Stevenson, 2005 ^47^
All subjects, dose 20 μg/d | 1 | 892 | 0.35 | (0.22, 0.55)
All subjects, dose 40 μg/d | 1 | 882 | 0.31 | (0.19, 0.50)
Subjects with severe osteoporosis | 1 | 892 | 0.35 | (0.22, 0.55)
Non-vertebral
Stevenson, 2005 ^47^
All subjects, dose 20 μg/d | 1 | 1,085 | 0.65 | (0.43, 0.98)
All subjects, dose 40 μg/d | 1 | 1,096 | 0.60 | (0.39, 0.91)
Subjects with severe osteoporosis | 1 | 1,085 | 0.65 | (0.43, 0.98)
Hip
Stevenson, 2005 ^47^
Subjects with severe osteoporosis | 1 | NR | 0.50 | (0.09, 2.73)
Wrist
Stevenson, 2005 ^47^
Subjects with severe osteoporosis | 1 | NR | 0.54 | (0.22, 1.35)
Humerus
Stevenson, 2005 ^47^
Subjects with severe osteoporosis | 1 | NR | 0.80 | (0.22, 2.98)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

We identified three RCTs ^194^ – ^196^ not included in the review that describe the number of fractures among subjects treated with teriparatide and placebo (Table 23). The study population in one of these studies was postmenopausal women with high risk for fracture. ^194^ The population in the other two studies was men with osteoporosis at intermediate risk for fracture participating in the same trial. ^195,^ ^196^

Table 23 Risk of fracture for teriparatide, relative to placebo, by fracture group

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, teriparatide | Number of fractures, placebo | Odds ratio (95% CI)
ALL FRACTURES
Kaufman, 2005 ^196^ | 30 months | moderate or severe facture | Intermediate | 2/176† | 7/103 | 0.16 (0.04, 0.65)
VERTEBRAL
Gallagher, 2005 ^194^ | 21 months | vertebral fracture | High | 22/403 | 62/398 | 0.34 (0.22, 0.54)
Kaufman, 2005 ^196^ | 30 months | vertebral fracture | Intermediate | 10/176† | 12/103 | 0.44 (0.18, 1.09)
NON-VERTEBRAL
Gallagher, 2005 ^194^ | 21 months | nonvertebral fracture | High | 30/467 | 46/464 | 0.63 (0.39, 1.00)
Orwoll, 2003 ^195^ | 11 months | nonvertebral fractures | Intermediate | 3/290† | 3/147 | 0.48 (0.09, 2.62)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, OR 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† 20ug and 40ug dose groups combined.

Fracture was the primary outcome in the study among postmenopausal females. This study demonstrated a reduced risk of vertebral (OR 0.34, 95% CI 0.22, 0.54) and non-vertebral (OR 0.63, 95% CI 0.39, 1.00) fractures for teriparatide relative to placebo at 21 months.

The other two studies report data at 11 ^195^ and 18 ^196^ months from the same trial. Fracture data were reported as adverse events and as secondary outcomes at the 11- and 18-month points, respectively. No significant difference in non-vertebral fractures between teriparatide and placebo was found at 11 months. A significant reduction in the risk of combined fractures (OR 0.16, 95% CI 0.04, 0.65) and a non-significant reduction in vertebral fractures (OR 0.44, 95% CI, 0.18, 1.09) for teriparatide relative to placebo was reported at 18 months.

#### Selective Estrogen Receptor Modulators (SERM)

##### Raloxifene

We identified three meta-analyses ^47,^ ^48,^ ^55^ that pooled data from four different RCTs to describe the effect of raloxifene on fracture risk reduction relative to placebo or no treatment among postmenopausal women. The RCTs included in these meta-analyses are detailed in Table 24. These meta-analyses reported risk estimates for vertebral, non-vertebral, hip, and wrist fractures (Table 25).

Table 24 Randomized controlled trials included in meta-analyses of effect of raloxifene on fracture relative to placebo or no treatment

| Meta-analyses (Author, year)
RCTs (Author, year) | Schachter, 2005 ^48^ | | Stevenson, 2005 ^47^ | | | | Seeman, 2006 ^55^
| Fracture Type
| Vertebral | Non-vertebral | Vertebral | Non-vertebral | Hip | Wrist | Vertebral
Ettinger, 1999 ^200^ | X | | * | * | * | * | X
Jolly, 2003 ^201^ | | | | | | | X
Lufkin, 1998 ^202^ | X | | * | * | * | | X
Morii, 2003 ^203^ | | | | | | | X

X= Included in pooled analysis;

* identified but not included in pooled analysis.

Table 25 Risk estimates of fracture for raloxifene relative to placebo or no treatment among postmenopausal women*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Schachter, 2005 ^48^
Ettinger study at four years | 1 | 7,705 | 0.60 | (0.52, 0.69)
Ettinger and Lufkin studies at four years | 2 | 7,848 | 0.81 | (0.43, 1.51)
Stevenson, 2005 ^47^
Women with severe osteoporosis | 1 | NR | 0.69 | (0.56, 0.86)
Women with severe osteoporosis or osteoporosis | 1 | 4,551 | 0.65 | (0.53, 0.79)
Women with osteoporosis | 1 | NR | 0.53 | (0.35, 0.79)
Women with osteopenia | 1 | NR | 0.53 | (0.32, 0.88)
Seeman, 2006 ^55^
60 mg | 5 | 5,600 | 0.60 | (0.49, 0.74)
120/150mg | 4 | 5,403 | 0.51 | (0.41, 0.64)
Non-vertebral
Stevenson, 2005 ^47^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 0.92 | (0.79, 1.07)
Hip
Stevenson, 2005 ^47^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 1.12 | (0.65, 1.95)
Wrist
Stevenson, 2005 ^47^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 0.89 | (0.68, 1.15)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

We identified two RCTs not included in the meta-analysis that describe the number of fractures among subjects treated with raloxifene relative to placebo (Table 26). One study population was postmenopausal women with intermediate risk for fracture. ^166^ Fracture data were collected as adverse events. There was no statistical difference in fracture risk between raloxifene and placebo, but the study was not powered to detect such a difference.

Table 26 Risk of vertebral fracture for raloxifene, relative to placebo*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, serm | Number of fractures, placebo | Odds ratio (95% CI)
Reid, 2004 ^166^ | 36 months | Vertebral fracture | Intermediate | 4/193† | 1/90 | 1.72 (0.26, 11.05)
Barrett-Connor, 2006 ^199^ | 5.6 years | Clinical vertebral | Unknown risk | 64/5,044 | 97/5,057 | 0.66 (0.48. 0.90)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† 60 mg and 150 mg dose groups combined.

The other study was the RUTH (Raloxifene Use for The Heart) trial. ^199^ This trial was designed to study the effects of raloxifene on cardiovascular events and breast cancer in post-menopausal women. Fractures were a secondary outcome. Raloxifene subjects had lower odds of clinical vertebral fractures relative to placebo (OR 0.66, 95% CI 0.48, 0.90). There was no substantial difference in clinical nonvertebral fractures.

##### Tamoxifen

We identified one RCT ^204^ that describes the number of fractures among subjects treated with tamoxifen relative to placebo (Table 27). The study population in this study comprised women older than 60 or women aged 35–59 with increased risk for breast cancer. Fracture was a secondary outcome for this study. There was no statistical difference in fracture risk between tamoxifen and placebo, for any type of fracture (Table 27).

Table 27 Risk of vertebral fracture for tamoxifen, relative to placebo*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, /SERM | Number of fractures, placebo | Odds ratio (95% CI)
Fisher, 1998 ^204^ | 60 months | spine fracture | 4 | 12/6576 | 22/6599 | 0.56 (0.28, 1.09)
Fisher, 1998 ^204^ | 60 months | Radius, Colle's | 4 | 14/6576 | 23/6599 | 0.62 (0.32, 1.17)
Fisher, 1998 ^204^ | 60 months | other lower radius | 4 | 66/6576 | 63/6599 | 1.05 (0.74, 1.49)
Fisher, 1998 ^204^ | 60 months | hip | 4 | 12/6576 | 22/6599 | 0.56 (0.28, 1.09)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Testosterone

We did not identify any studies that evaluated the risk of fracture with testosterone relative to placebo. Studies of testosterone use and its effects on bone health have been limited in their outcome measures to that of bone density.

#### Vitamins and Minerals

##### Calcium

We identified one meta-analysis ^49^ that describes the effect of calcium supplementation on fracture risk reduction relative to placebo or no treatment, among postmenopausal women. The meta-analysis pooled data from five different RCTs (Table 28). Vitamin D was given to all subjects in one of the studies (single 300,000 IU dose at study inception) ^205^ but was not used in any of the other studies. This meta-analysis reported pooled risk estimates for vertebral and non-vertebral fractures, neither of which were statistically significant (Table 29).

Table 28 Randomized controlled trials included in meta-analysis of effect of calcium on fracture relative to placebo or no treatment

Meta-analysis (Author, year)
RCTs (Author, year) | Shea, 2002 ^49^
| Vertebral | Non-vertebral
Chevally, 1994 ^205^ | X | X
Hansson, 1987 ^208^ | X
Recker, 1996 ^209^ | X
Reid, 1993 ^210^ | X
Riggs, 1998 ^211^ | X | X

X= Included in pooled analysis.

Table 29 Pooled risk estimates of fracture for calcium relative to placebo or no treatment among postmenopausal women

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Shea, 2002 ^49^ | 5 | 576 | 0.77 | (0.54, 1.09)
Non-vertebral
Shea, 2002 ^49^ | 2 | 222 | 0.86 | (0.43, 1.72)

We identified four RCTs ^65,^ ^92,^ ^206,^ ^207^ not included in the meta-analysis that describe the number of fractures among subjects treated with calcium relative to placebo (Table 30). The study population in three of these studies was postmenopausal women with high ^65,^ ^206^ or intermediate ^207^ risk for fracture. The populations in the other study included men and women with asthma ^92^ who had an intermediate risk for fracture.

Table 30 Risk of fracture for calcium, relative to placebo, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, calcium | Number of fractures, placebo or control† | Odds ratio (95% CI)
ALL FRACTURES
Campbell, 2004 ^92^ | 60 months | New symptomatic vertebral and non-vertebral fractures | Intermediate | 7/85 | 7/95† | 1.13 (0.38, 3.35)
Prince, 2006 ^206^ ** | 60 months | Any site fracture | High | 110/728 | 126/728 | 0.85 (0.64, 1.12)
Prince, 2006 ^206^ *** | 60 months | Any site fracture | High | 43/422 | 63/409 | 0.63 (0.42, 0.94)
Grant, 2005 ^65^ | 62 months | New fractures | High | 189/1311 | 196/1332 | 0.98 (0.79, 1.21)
VERTEBRAL FRACTURES
Campbell, 2004 ^92^ | 60 months | New symptomatic or semi-quantittive vertebral fractures | Intermediate | 15/85 | 19/95† | 0.86 (0.41, 1.81)
Grant, 2005 ^65^ | 62 months | Clinical vertebral fracture | High | 3/1311 | 1/1332 | 2.77 (0.39, 19.65)
Prince, 2006 ^206^ ** | 60 months | Vertebral deformity | High | 44/431 | 50/450 | 0.91 (0.59, 1.40)
Prince, 2006 ^206^ *** | 60 months | Vertebral deformity | High | 22/306 | 32/305 | 0.66 (0.38, 1.16)
Reid, 2006 ^207^ | 60 months | Vertebral fracture | Intermediate | 27/739 | 38/732 | 0.70 (0.42, 1.14)
NON-VERTEBRAL
Prince, 2006 ^206^ ** | 60 months | Any appedicular site fracture | High | 83/728 | 94/729 | 0.87 (0.64, 1.19)
Prince, 2006 ^206^ *** | 60 months | Any appredicular site fracture | High | 39/419 | 58/411 | 0.63 (0.41, 0.96)
HIP
Grant, 2005 ^65^ | 62 months | Proximal femur fracture | High | 49/1311 | 41/1332 | 1.22 (0.80, 1.86)
Prince, 2006 ^206^ ** | 60 months | Proximal femur | High | 11/733 | 6/750 | 1.86 (071, 4.83)
Prince, 2006 ^206^ *** | 60 months | Proximal femur | High | 5/417 | 3/429 | 1.70 (0.42, 6.85)
Reid, 2006 ^207^ | 60 months | hip fracture | | 17/739 | 5/732 | 3.0 (1.29, 6.95)
WRIST
Grant, 2005 ^65^ | 62 months | Distal forearm fracture | High | 33/1311 | 28/1332 | 1.20 (0.72, 2.00)
Prince, 2006 ^206^ ** | 60 months | Wrist or hand | High | 21/724 | 20/741 | 1.08 (0.58, 2.00)
Prince, 2006 ^206^ *** | 60 months | Wrist or hand | High | 10/417 | 12/414 | 0.82 (0.35, 1.92)
Reid, 2006 ^207^ | 60 months | Distal forearm fracture | Intermediate | 28/739 | 44/732 | 0.62 (0.39, 1.00)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

** Intention to treat analysis.

*** Compliant with medication.

† Control group.

Although fracture was the primary outcome for all of these studies, enrollment was lower than anticipated and the sample size was not sufficiently large to detect differences in fracture risk between calcium and placebo in one study. ^92^

There were no statistically significant differences in the risk of fracture for calcium relative to placebo in the remaining three trials using intention to treat analyses. However, two of the studies ^65,^ ^206^ reported high rates of non-compliance with calcium. In one study, ^206^ in which 57% of the subjects took at least 80% of their calcium pills, the participants in the calcium group had reduced fracture incidence compared with the placebo group (10.2% vs. 15.4%; hazard ratio, 0.66; 95% CI, 0.45–0.97). In the other study, ^65^ 78% took at least 80% of the calcium pills; however an analysis of compliant subjects was not performed for this study.

##### Vitamin D

We identified six meta-analyses ^47,^ ^50^ – ^52,^ ^58,^ ^61^ that pooled data from 39 different RCTs to describe the effect of vitamin D on fracture risk reduction relative to placebo or no treatment. The populations included in these meta-analyses were men or women with osteoporosis, ^51,^ ^58,^ ^61^ older adults, ^52^ and postmenopausal women. ^50,^ ^58,^ ^61,^ ^212^ The RCTs included in these meta-analyses are detailed in Table 31. These meta-analyses reported risk estimates for vertebral, non-vertebral, and hip fractures (Table 32).

Table 31 Randomized controlled trials included in meta-analyses of effect of vitamin D on fracture relative to placebo or no treatment

| Meta-analyses (Author, year)
RCTs (Author, year) | Avenell, 2005 ^51^ | | | Bischoff-Ferrari, 2005 ^52^ | | Papadimitropoulos, 2002 ^50^ | | Stevenson, 2005 ^47^ | | Richy, 2004 ^61^ | | Richy, 2005 ^58^
| Fracture Type
| V | NV | H | NV | H | V | NV | V | NV | V | NV | V | NV
Adachi, 1996 ^215^ | | | | | | | | | | | | X
Aloia, 1988 ^216^ | | | | | | | | X | | X
Avenell, 2004 ^217^ | X | | X
Baeksgaard, 1998 ^218^ | | | | | | X
Cannigia, 1984 ^219^ | | | | | | X | | X
Chapuy, 1994 ^220^ | | | | X | X
Chapuy, 1992 ^221^ | | | | | | | X | | | | | | X
Chapuy, 2002 ^222^ | | | | X | X
Dawson-Hughes, 1997 ^223^ | | | | X | X | | X | | | | | X
Dukas, 2004 ^224^ | | X
Ebeling, 2001 ^225^ | | | | | | | | | | X | | X
Gallegher, 1989 ^226^ | | | | | | | | | | X | | | X
Gallegher, 1990 ^227^ | | | | | | | | | | X | | X
Gallagher, 2001 ^174^ | | | X | | | X | | | X | X | X | X | X
Gorai,1999 ^228^ | | X
Grant, 2005 ^229^ | X
Guesens, 1986 ^230^ | | | | | | X
Harwood, 2004 ^231^ | | | X
Hayashi, 1992 ^232^ | | | | | | | | | | X | | X
Komulainen, 1998 ^181^ | | | | | | | | | | | | | X
Lipps, 1996 ^233^ | | | X | X | X | | X | | | | | | X
Menczel, 1994 ^234^ | | | | | | | | | | | X | | X
Meyer, 2002 ^235^ | | | X | X | X | | | | | | | | X
Oriomo, 1987 ^236^ | | | | | | X
Oriomo, 1994 ^237^ | | | | | | X | X | | | X | | X
Ott, 1989 ^238^ | | | | | | X | X | X | X
Peacock, 2000 ^239^ | X
Pfeifer, 2000 ^240^ | | | | X | X | | | | | | | | X
Sambrook, 2000 ^241^ | | | | | | | | | | X | | X
Sato, 1997 ^242^ | | | X | | | | | | | | X | | X
Sato, 1999a ^243^ | | X | X | | | | | | | | X | | X
Sato, 1999b ^244^ | | | X
Shiraki, 1996 ^245^ | | | | | | | | | | X | | | X
Smith, 2004 ^246^ | | | X
Stempfle, 1999 ^247^ | | | | | | | | | | | | X
Tilyard, 1992 ^248^ | | | | | | X | X | | | X | | X
Trivedi, 2003 ^249^ | X | | X | X | X | | | | | | | X | X
Ushirooyama, 2001 ^141^ | | X

X= Included in pooled analysis;

* identified but not included in pooled analysis

Table 32 Risk estimates of fracture for vitamin D relative to placebo or no treatment*

Type of fracture | # studies | Sample size | RR | (95% CI)
Vertebral fractures
Avenell, 2005 ^51^
Standard vitamin-D [D2, D3, or 25(OH)D]
Not selected on basis of prior osteoporotic fracture | 2 | 2,953 | 0.96 | (0.42, 2.21)
Selected on basis of prior osteoporotic fracture | 1 | 2745 | 3.97 | (0.44, 35.45)
Either selected or not selected on basis of prior osteoporotic fracture | 3 | 5698 | 1.13 | (0.50, 2.55)
Papadimitropoulos, 2002 ^50^
Standard vitamin-D [D2, D3, or 25(OH)D] | 1 | 160 | 0.33 | (0.01, 8.05)
Calcitriol (1,25-OH vitamin D) | 7 | 970 | 0.64 | (0.44, 0.92)
Either Standard vitamin-D or Calcitriol | 8 | 1130 | 0.63 | (0.45, 0.88)
Richy, 2004 ^61^
Primary osteoporosis | 9 | 1665 | 0.53 | (0.47, 0.60)
Calcitriol | 6 | 896 | 0.52 | (0.41, 0.67)
Alphacalcidol | 3 | 769 | 0.53 | (0.46, 0.61)
GC-induced (calcitriol only) | 2 | 106 | 0.33 | (0.07, 1.51)
Richy, 2005 ^58^
Primary osteoporosis (24 mos)
Vitamin D analogues | 5 | 1972 | 15%† | (10, 20%)
Standard vitamin D | 2 | 3075 | 1.6%† | (0.4, 2.6%)
GC treatment
Vitamin D analogues | 3 | 300 | 9% | (-2, 22%)
Standard vitamin D | 1 | 62 | 6% | (-23, 10%)
Stevenson, 2005 ^47^
Women with severe osteoporosis | 3 | 109 | 1.02 | (0.44, 2.32)
Elderly women not selected for BMD | 1 | NR | 4.44 | (0.50, 39.03)
Non-vertebral
Avenell, 2005 ^51^
Alphacalcidiol
Not selected on basis of prior osteoporotic fracture | 2 | 466 | 0.40 | (0.05, 3.08)
Bischoff-Ferrari, 2005 ^52^
All doses (D2, D3) | 7 | 9820 | 0.83 | (0.70, 0.98)
700–800IU/d | 5 | 6098 | 0.77 | (0.68, 0.87)
400IU/d | 2 | 3722 | 1.03 | (0.86, 1.24)
Stevenson, 2005 ^47^
Women with severe osteoporosis or osteoporosis | 1 | 86 | 2.50 | (0.51, 12.19)
Elderly women not selected for BMD | 1 | 213 | 0.46 | (0.17, 1.27)
Papadimitropoulos, 2002 ^50^
Standard vitamin-D [D2, D3, or 25(OH)D] | 3 | 5399 | 0.78 | (0.55, 1.09)
Calcitriol (1,25-OH vitamin D) | 3 | 788 | 0.87 | (0.29, 2.59)
Either Standard vitamin-D or Calcitriol | 6 | 6187 | 0.77 | (0.57, 1.04)
Richy, 2004 ^61^ | 11 | 1310 | 0.52 | (0.46, 0.59)
Calcitriol | 5 | 381 | 0.52 | (0.41, 0.66)
Alphacalcidol | 6 | 929 | 0.52 | (0.45, 0.59)
Richy, 2005 ^58^
Primary osteoporosis
Vitamin D analogues | 7 | 913 | 8%† | (2, 13%)
Standard vitamin D | 6 | 7058 | 2%† | (1, 3%)
Hip
Avenell, 2005 ^51^
Standard vitamin-D [D2, D3, or 25(OH)D]
Not selected on basis of prior osteoporotic fracture | 4 | 15948 | 1.20 | (0.98, 1.47)
Selected on basis of prior osteoporotic fracture | 3 | 2820 | 1.08 | (0.72, 1.62)
Either selected or not selected on basis of prior osteoporotic fracture | 7 | 18668 | 1.17 | (0.98, 1.41)
Alphacalcidiol
Not selected on basis of prior osteoporotic fracture | 3 | 239 | 0.16 | (0.04, 0.69)
Calcitriol (1,25-OH vitamin D)
Not selected on basis of prior osteoporotic fracture | 1 | 246 | 0.33 | (0.01, 8.10)
Bischoff-Ferrari, 2005 ^52^
All doses (D2, D3) | 5 | 9294 | 0.88 | (0.69, 1.13)
700–800IU/d | 3 | 5572 | 0.74 | (0.61, 0.88)
400IU/d | 2 | 3722 | 1.15 | (0.88, 1.50)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

† Results expressed as rate difference (difference in fracture rate between treatment and placebo or no treatment).

One meta-analysis, ^51^ which included RCTs and quasi-randomized trials of vitamin D and its analogues, found that vitamin D alone had no statistically significant effect on hip, vertebral, or any new fracture. Vitamin D with calcium marginally reduced hip fractures (RR 0.81, 95% C.I. 0.68–0.96) but did not have any effect on vertebral fractures. The effect appeared to be restricted to those living in institutional care.

A second meta-analysis evaluated the efficacy of vitamin D treatment in preventing postmenopausal osteoporosis and included 25 RCTs—published between 1966 and 1999—of standard or hydroxylated vitamin D with or without calcium supplementation or a control. ^50^ This analysis concluded that vitamin D reduced the risk of vertebral fractures (RR=0.63, 95% C.I. 0.45–0.88). A non-significant trend was seen for nonvertebral fractures (RR=0.77, p=0.09). The authors acknowledge that inferences from these analyses are limited by variability in design, difference in vitamin D formulation, differences in populations studied, and inconsistent outcome measures.

The third meta-analysis evaluated fracture prevention with vitamin D supplementation and included studies with men. ^52^ Five RCTs with hip fracture as an outcome and seven RCTs with nonvertebral fracture as an outcome were included. All trials used standard vitamin D_3_ (cholecalciferol). A vitamin D dose of 700 to 800 I.U. daily was associated with a reduced risk of hip fracture (RR=0.74, 95% C.I. 0.61–0.88) and a reduced risk of any nonvertebral fracture (RR=0.77, 95% C.I. 0.68–0.8). Doses of 400 I.U. daily were not effective in preventing hip and nonvertebral fractures.

The fourth meta-analysis ^47^ evaluated the effect of vitamin D on fractures in postmenopausal women. This meta-analyses stratified findings based on whether subjects had osteopososis at study enrollment (according to BMD). In this meta-analysis, vitamin-D had no effect on fracture in either stratum.

The fifth meta-analysis ^61^ evaluated the effects of two vitamin D analogs - alfacalcitol and calcitriol - on the risk for fracture in men and women with osteoporosis. Both analogs reduced the risk of overall fracture rate, vertebral fracture rate, and nonvertebral fracture rate. Calcitriol had similar efficacy to alphacalcidol; however, no study included in the meta-analysis tested them head to head. Participants were also stratified based on whether the osteoporosis was primary or secondary (glucocorticoid-induced [GC]): vitamin D analogs did not significantly decrease the risk for fracture in participants with GC-induced osteoporosis.

The sixth meta-analysis ^58^ evaluated the effects of the two vitamin D analogs as well as native vitamin D on men and Women's fracture risk (expressed as rate difference - RD - the difference in fracture rate between the treatment and placebo groups). The RDs for the analogs and native vitamin D were significant at 24 and 36 months. Although the RDs for the analogues were greater than for native vitamin D, there were no head-to-head comparisons. No significant effect was seen on participants with GC-induced osteoporosis.

We identified four RCTs ^65,^ ^93,^ ^213,^ ^214^ not included in the meta-analyses that described the number of fractures among subjects treated with vitamin D compared with placebo (Table 33). The study population in all of these studies was at high risk for fracture. The majority of the patients in three of these were postmenopausal women, ^65,^ ^93,^ ^214^ although one large study included 793 men. ^65^ The other study include male and female renal transplant recipients. ^213^ Fracture was the primary outcome in one ^65^ and a secondary outcome in the others.

Table 33 Risk of vertebral fracture for vitamin D, relative to placebo*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, vit d | Number of fractures, placebo | Odds ratio (95% CI)
ALL FRACTURES
Grant, 2005 ^65^ | 62 months | New fractures | High | 212/1343 | 196/1332 | 1.09 (0.88, 1.34)
Torres, 2004 ^213^ | 12 months | symptomatic fracture | High | 0/41 | 0/45 | NC
VERTEBRAL
Grant, 2005 ^65^ | 62 months | Clinical vertebral | High | 4/1343 | 1/1332 | 1.17 (0.71, 1.95)
Ishida, 2004 ^93^ | 24 months | vertebral | High | 11/66 | 17/66 | 0.58 (0.25, 1.34)
HIP
Grant, 2005 ^65^ | 62 months | Proximal femur | High | 47/1343 | 41/1332 | 1.14 (0.75, 1.75)
Sato, 2005 ^214^ | 24 months | Hip | High | 0/24 | 4/24 | 0.12 (0.01, 0.90)
WRIST
Grant, 2005 ^65^ | 62 months | Distal forearm | High | 33/1343 | 28/1332 | 1.17 (0.71, 1.95)
Ishida, 2004 ^93^ | 24 months | vertebral | High | 11/66 | 17/66 | 0.58 (0.25, 1.34)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

No difference in the risk for fracture for vitamin D relative to placebo was detected in the single study with sufficient sample size to detect such a difference. ^65^ One study that included postmenopausal women with hemiplegia after stroke did demonstrate a significant reduction in risk for hip fracture for vitamin D relative to placebo (OR 0.12, 95% CI 0.016, 0.89). ^214^ The other two studies ^93,^ ^213^ did not detect a difference but were not powered to do so.

##### Calcium plus Vitamin D

We identified three RCTs ^63^ – ^65^ that described the number of fractures among subjects treated with calcium plus vitamin D compared with placebo (Table 34). The study population in each of these studies was predominantly postmenopausal women with high ^65^ or intermediate ^63,^ ^64^ risk for fracture. Fracture was a primary outcome in each of these studies, and all were powered to detect differences in fracture risk between study arms. Fracture risk did not differ significantly for calcium plus vitamin D compared with placebo for any type of fracture in any of the studies (Table 34).

Table 34 Risk of vertebral fracture for calcium plus vitamin D, relative to placebo*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, Calcium plus vit D | Number of fractures, placebo or control | Odds ratio (95% CI)
ALL FRACTURES
Grant, 2005 ^65^ | 62 months | New fractures | High | 104/1306 | 196/1332 | 0.95 (0.76, 1.18)
Jackson, 2006 ^63^ | 84 months | Total fracture | Intermediate | 2101/18176 | 2158/18106 | 0.97 (0.91, 1.03)
Porthouse, 2005 ^64^ | 24 months | All fractures | Intermediate | 24/607 | 22/602 | 1.09 (0.6, 1.96)
VERTEBRAL
Grant, 2005 ^65^ | 62 months | Clinical vertebral | High | 0/1306 | 1/1332 | 0.14 (0, 6.96)
Jackson R, 2006 ^63^ | 84 months | Clinical vertebral | Intermediate | 181/18176 | 197/18106 | 0.91 (0.75, 1.12)
HIP
Grant, 2005 ^65^ | 62 months | Proximal femur | High | 46/1306 | 41/1332 | 1.15 (0.75, 1.76)
Jackson, 2006 ^63^ | 84 months | Hip fracture | Intermediate | 175/18176 | 199/18106 | 0.87 (0.71, 1.07)
Porthouse, 2005 ^64^ | 24 months | Hip fracture | Intermediate | 5/607 | 2/602 | 2.35 (0.53, 10.36)
WRIST
Grant, 2005 ^65^ | 62 months | Distal forearm | High | 33/1306 | 28/1332 | 1.21 (0.73, 2.01)
Jackson, 2006 ^63^ | 84 months | Lower arm or wrist | Intermediate | 565/18176 | 557/18106 | 1.01 (0.9, 1.14)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

Within class comparisons

Among the classes of drugs included in this report, two include two or more drugs that were considered in this report: the bisphosphonates and SERM. We identified nine RCTs with comparisons across different bisphosphonates and one with a comparison across different SERMs.

#### Bisphosphonates

We identified nine RCTs ^68,^ ^250^ – ^257^ that included head-to-head comparisons of four different bisphosphonates pairs (Table 35). For the most part, these studies were not designed or powered to compare fracture outcomes but rather to compare changes in intermediate outcomes such as bone mineral density and changes in markers of bone turnover. Only one of the head-to-head trials ^250^ was designed to compare facture outcomes; this study was designed to compare risedronate to etidronate for the prevention of vertebral fractures.

Table 35 Head to head trials of bisphosphonates with fracture outcomes

| Alendronate | Etidronate | Ibandronate | Pamidronate | Risedronate | Zoledronic acid
Alendronate | ***********
Etidronate | 2 | ***********
Ibandronate | 0 | 0 | ***********
Pamidronate | 0 | 0 | 0 | ***********
Risedronate | 4 | 2 | 1 | 0 | ***********
Zoledronic acid | 0 | 0 | 0 | 0 | 1 | ***********

##### Alendronate vs. Etidronate

We identified two RCTs ^252,^ ^253^ that compared fracture risk between treatment with alendronate and etidronate. Fracture was a secondary outcome in each of these studies and neither was powered to detect differences in fracture across groups. The study populations were postmenopausal women with osteoporosis ^253^ and osteopenic women with primary biliary cirrhosis. ^252^ Both studies were small and neither demonstrated any difference in fracture risk between alendronate and etidronate (Table 36).

Table 36 Fractures with alendronate relative to etidronate, by fracture type*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, alendronate | Number of fractures, etidronate | Odds ratio (95% CI)
VERTEBRAL
Guanabens, 2003 ^252^ | 24 months | vertebral | Intermediate | 0/13 | 0/13 | NC
Iwamoto, 2003 ^253^ | 6 months | vertebral | High | 0/25 | 1/25 | 0.14 (0.00, 6.82)
NONVERTEBRAL
Guanabens, 2003 ^252^ | 24 months | non-vertebral | Intermediate | 2/13 | 1/13 | 2.06 (0.19, 21.85)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

NC=not calculable

##### Alendronate vs. Risedronate

We identified four RCTs ^68,^ ^254,^ ^255,^ ^257^ that compared fracture risk between treatment with alendronate and risedronate. Fracture data were collected as a secondary outcome in one of these studies ^255^ and as adverse events in the other three; ^68,^ ^254,^ ^257^ none were powered to detect differences in fracture across groups. All studies were restricted to women with osteoporosis or osteopenia. Three of the studies specified that the women were postmenopausal. ^68,^ ^254,^ ^257^ Across all doses and all type of fractures that were assessed, there were no differences in fracture risk between alendronate and risedronate (Table 37).

Table 37 Fractures with alendronate relative to risedronate, by fracture type among women with osteoporosis*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, alendronate | Number of fractures, risedronate | Odds ratio (95% CI)
ALL FRACTURES
Bonnick, 2006 ^257^ | 24 months | clinical fracture | Intermediate | 34/410 | 34/415 | 1.01 (0.62, 1.66)
Hosking, 2003 ^68^ | 12 months | fracture, clinical | High | 6/172 | 6/178 | 1.04 (0.33, 3.27)
Rosen, 2005 ^254^ | 12 months | fracture | Intermediate | 26/520 | 20/533 | 1.35 (0.75, 2.43)
Muscoso, 2004 ^255^ | 12 months | total fractures | High | 2/1000 | 0/100 | 3.01 (0.02, 373.9)
VERTEBRAL
Muscoso, 2004 ^255^ | 12 months | vertebral | High | 2/1000 | 0/100 | NC
Muscoso, 2004 ^255^ | 24 months | vertebral | High | 4/1000 | 0/100 | NC
HIP
Muscoso, 2004 ^255^ | 12 months | femoral | High | 1/1000 | 0/100 | NC
Muscoso, 2004 ^255^ | 24 months | femoral | High | 2/1000 | 0/100 | NC
WRIST
Muscoso, 2004 ^255^ | 12 months | radial | High | 1/1000 | 0/100 | NC
Muscoso, 2004 ^255^ | 24 months | radial | High | 0/1000 | 0/100 | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

NC=not calculable

##### Etidronate vs. Risedronate

We identified two RCTs ^250,^ ^251^ that compared fracture risk between treatment with etidronate and risedronate. In one study, ^250^ incidence of new vertebral fractures was the primary outcome; this study had sufficient sample size to demonstrate noninferiority of risedronate to etidronate for the prevention of vertebral fractures. Fracture incidence was a secondary outcome in the other study ^251^ and it did not have power to detect differences in fracture incidence across groups. The inclusion criteria were postmenopausal women with osteoporosis for one study, ^250^ and men or women with osteoporosis for the other, although only 1% of the sample was male. ^251^ Neither study demonstrated any difference in fracture risk between etidronate and risedronate (Table 38).

Table 38 Fractures with etidronate relative to risedronate, by fracture type

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, etidronate | Number of fractures, risedronate | Odds ratio (95% CI)
Fukunaga, 2002 ^251^ | 11 months | non-vertebral | High | 4/117 | 7/118 | 0.57 (0.17,1.91)
Fukunaga, 2002 ^251^ | 11 months | vertebral | High | 2/111 | 0/101 | 6.81 (0.42, 110)
Kushida, 2004 ^250^ | 96 weeks | vertebral | High | 13/217 | 19/216 | 0.66 (0.32, 1.36)

##### Risedronate vs. Zoledronic Acid

We identified one RCT ^256^ that compared fracture risk between treatment with risedronate and with zoledronic acid. This study evaluated the effects of several antiresorptive treatments on bone mineral density among women with ovarian failure after allogeneic stem cell transplantation; fracture was a secondary outcome. There was no difference in fracture risk between risedronate and zoledronic acid, but the sample sizes were small and the study was not powered to detect differences (Table 39).

Table 39 Risk of fracture for risedronate relative to zoledronic acid, by fracture type

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, risedroante | Number of fractures, zoledronic acid | Odds ratio (95% CI)
Tauchmanova, 2006 ^256^ | 12 months | subclinical vertebral fractures | Intermediate | 2/15 | 3/15 | 0.63 (0.10, 4.15)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

#### Selective Estrogen Receptor Modulators

##### Raloxifene vs. Tamoxifen

We identified one RCT ^258^ that compared fracture risk between treatment with raloxifene and treatment with tamoxifen. This RCT evaluated the effects of raloxifene and tamoxifen on a number of outcomes including fracture among 19,747 postmenopausal women with increased risk for breast cancer. There was no difference in fracture risk between the agents (Table 40); the study was powered to detect differences.

Table 40 Risk of fracture for raloxifene relative to tamoxifen, by fracture type*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, raloxifene | Number of fractures, tamoxifen | Odds ratio (95% CI)
Vogel, 2006 ^258^ | 60 months | osteoporotic fractures | Low | 104/9726 | 96/9745 | 1.09 (0.82, 1.44)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, OR 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

Between class comparisons

We identified 16 RCTs ^65^ – ^67,^ ^82,^ ^91^ – ^93,^ ^166,^ ^255,^ ^256,^ ^259^ – ^264^ that included head-to-head comparisons of 11 different drug pairs (Table 41).

Table 41 Head to head trials between classes of agents used to treat or prevent osteoporosis that examined fracture outcomes

| BIsphosphonate | Calcitonin | Calcium | Estrogen | PTH | SERMS | Testosterone | Vitamin D | Exercise
BIsphosphonate | *************
Calcitonin | 2 | **********
Calcium | 2 | 0 | *********
Estrogen | 6 | 1 | 0 | ***********
PTH | 1 | 0 | 0 | 0 | ********
SERMS | 3 | 0 | 0 | 1 | 0 | ************
Testosterone | 0 | 0 | 0 | 0 | 0 | 0 | ***************
Vitamin D | 2 | 3 | 1 | 1 | 0 | 0 | 0 | *********

##### Bisphosphonate vs. Calcitonin

We identified two studies ^93,^ ^261^ that compared the effects of a bisphosphonate and calcitonin on fracture incidence. Fractures were secondary outcomes in each, and neither was powered to detect differences in fracture rate across arms. In one study, the population was postmenopausal women with osteoporosis; ^93^ in the other, organ transplant recipients that were primarily male. ^261^ The bisphosphonate in both studies was etidronate. Both studies were small, and no difference in fracture incidence between etidronate and calcitonin was found in either (Table 42).

Table 42 Fractures with etidronate relative to calcitonin, by fracture type*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, etidronate | Number of fractures, calcitonin | Odds ratio (95% CI)
Ishida, 2004 ^93^ | 24 months | vertebral | High | 8/66 | 8/66 | 1.00 (0. 35, 2.83)
Garcia-Delgado, 1997 ^261^ | 18 months | vertebral | High | 3/14 | 4/13 | 0.63 (0. 12, 3.39)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline OR 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Bisphosphonate vs. Calcium

We identified two studies ^92,^ ^263^ that compared the effects of a bisphosphonate and calcium on fracture incidence (Table 43). One study assessed etidronate, ^92^ the other pamidronate. ^263^ The study populations comprised individuals who required long-term glucocorticoids; in one study, they were required for asthma ^92^ , and in the other study, they were required primarily for connective tissue disease. ^263^ Although fracture was the primary outcome of one study, ^92^ it did not reach target enrollment. Fracture was the secondary outcome of the other study. ^263^ There were no significant differences in the risk of fracture for bisphosphonates relative to calcium in either study. Neither study had sufficient sample size to detect such a difference in risk across study arms.

Table 43 Fractures with bisphosphonates relative to calcium, by bisphosphonate*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, etidronate | Number of fractures, calcium | Odds ratio (95% CI)
ETIDRONATE
Campbell, 2004 ^92^ | 60 months | New symptomatic vertebral or non-vertebral | Intermediate | 5/81 | 7/85 | 0.74 (0. 23, 2.38)
PAMIDRONATE
Boutsen, 1997 ^263^ | 12 months | Atraumatic vertebral fracture | Intermediate | 1/14 | 0/13 | 6.88 (0.14, 347.65)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Bisphosphonate vs. Estrogen

We identified six studies that compared a bisphosphonate alone with estrogen: three compared alendronate and estrogen, ^66,^ ^67,^ ^82^ two compared etidronate and estrogen, ^91,^ ^93^ and one compared both risedronate and zoledronic acid to estrogen. ^256^ There was no difference in fracture incidence between any of the bisphosphonates and estrogen (Table 44). Fracture data were collected as adverse events in the three studies that compared alendronate and estrogen; ^66,^ ^67,^ ^82^ they were collected as secondary endpoints in the studies that compared etidronate, risedronate, or zoledronic acid and estrogen. ^91,^ ^93,^ ^256^ None of the studies was powered to detect differences in fracture rates across study arms.

Table 44 Fractures with bisphosphonate relative to estrogen, among postmenopausal women*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, bisphosphonate | Number of fractures, estrogen | Odds ratio (95% CI)
ALENDRONATE
Hosking, 1998 ^82^ | 24 months | non-vertebral | 1 | 44/897 | 6/204† | 1.58 (0. 56, 4.43)
Bone, 2000 ^66^ | 24 months | clinical fracture | 1 | 5/92 | 10/143 | 0.77 (0. 26, 2.25)
Greenspan, 2003 ^67^ | 34 months | clinical fracture | 2 | 7/93 | 5/93 | 1.43 (0. 44, 4.58)
ETIDRONATE
Ishida, 2004 ^93^ | 24 months | vertebral | 1 | 8/66 | 7/66† | 1.16 (0. 40, 3.39)
Wimalawansa, 1998 ^91^ | 48 months | non-vertebral | 1 | 1/14 | 1/15 | 1.07 (0. 06, 18.10)
Wimalawansa, 1998 ^91^ | 48 months | vertebral | 1 | 3/14 | 2/15 | 1.73 (0. 26, 11.50)
RISEDRONATE
Tauchmanova, 2006 ^256^ | 12 months | Subclinical vertebral | 2 | 2/15 | 1/15 | 2.05 (0.20, 21.36)
ZOLEDRONIC ACID
Tauchmanova, 2006 ^256^ | 12 months | Subclinical vertebral | 2 | 3/15 | 1/15 | 3.05 (0.38, 24.18)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† Estrogen plus progesterone.

##### Bisphosphonate vs. PTH

We identified one study ^259^ on fracture incidence among postmenopausal women that compared a bisphosphonate-alendronate-with PTH. In this study, the likelihood of non-vertebral fracture was higher with alendronate than with PTH (OR 3.24, 95% CI 1.04–10.07). Fractures were secondary outcomes; the study was not powered to detect differences in fracture rates across arms (Table 45).

Table 45 Fractures with alendronate relative to PTH among postmenopausal women*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, Alendronate | Number of fractures, PTH | Odds ratio (95% CI)
Body, 2002 ^259^ | 14 months | non-vertebral | 1 | 10/73 | 3/73 | 3.24 (1.04, 10.07)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Bisphosphonate vs. SERMS

We identified three studies ^255,^ ^260,^ ^262^ that compared the effects of a bisphosphonate and a SERM on fracture incidence among women with osteoporosis. Two of the studies specified osteoporosis as an inclusion criterion; ^260,^ ^262^ the average age of the women enrolled in the other study was 68 years. ^255^ The SERM in all studies was raloxifene. Alendronate was compared with raloxifene in each of the studies. Risedronate was compared with raloxifene in one study. ^255^ There was no difference in fracture incidence between either of the bisphosphonates and raloxifene (Table 46). Data on fractures were collected as adverse events in two of the studies ^137,^ ^262^ and as secondary outcomes in the other. ^255^ Neither study was powered to detect differences in fracture rates across study arms.

Table 46 Fractures with bisphosphonates relative to raloxifene*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, bisphosphonate | Number of fractures, raloxifene | Odds ratio (95% CI)
ALENDRONATE
TOTAL FRACTURES
Luckey, 2004 ^260^ | 12 months | all clinical fractures | HIgh | 5/221 | 8/230 | 0.65 (0.22, 1.95)
Uchida, 2005 ^264^ | 12 months | Vertebral or nonvertebral | Intermediate | 22/713 | 20/699 | 1.08 (0.59, 2.0)
VERTEBRAL
Muscoso, 2004 ^255^ | 24 months | vertebral | High | 6/1000 | 0/100 | NC
Uchida, 2005 ^264^ | 12 months | Vertebral | Intermediate | 8/713 | 5/699 | 1.56 (0.52, 4.65)
NONVERTEBRAL
Uchida, 2005 ^264^ | 12 months | Nonvertebral | Intermediate | 14/713 | 15/699 | 0.94 (0.44, 1.91)
HIP
Muscoso, 2004 ^255^ | 24 months | femoral | High | 3/1000 | 0/100 | NC
Uchida, 2005 ^264^ | 12 months | Hip fracture | Intermediate | 1/713 | 2/699 | 0.5 (0.05, 4.84)
WRIST
Muscoso, 2004 ^255^ | 24 months | radial | High | 1/1000 | 0/100 | NC
Uchida, 2005 ^264^ | 12 months | Wrist | Intermediate | 6/713 | 8/699 | 0.74 (0.26, 2.11)
RISEDRONATE
VERTEBRAL
Muscoso, 2004 ^255^ | 24 months | vertebral | High | 0/100 | 0/100 | NC
HIP
Muscoso, 2004 ^255^ | 24 months | femoral | High | 0/100 | 0/100 | NC
WRIST
Muscoso, 2004 ^255^ | 24 months | radial | High | 0/100 | 0/100 | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

##### Bisphosphonate vs. Testosterone

We did not identify any studies that evaluated the risk of fracture for any bisphosphonate relative to testosterone.

##### Bisphosphonate vs. Vitamin D

We identified one meta-analysis ^265^ and two original studies ^93,^ ^261^ not included in the meta-analysis that compared the effects of a bisphosphonate and a vitamin D preparation on fracture incidence. The meta-analysis ^265^ pooled five studies that compared the effect of bisphosphonates with that of vitamin D analogs in decreasing the risk for vertebral fractures in patients taking glucocorticoids (Table 47). Data on fractures were collected as secondary outcomes in all studies, and no two studies compared the same bisphosphonate-vitamin D analog pair. Bisphosphonates were more effective than vitamin D analogs (RR 1.20 95% CI 0.32, 4.55).

Table 47 Randomized controlled trials included in meta-analysis of effect of vitamin D on fracture relative to bisphosphonates

| Meta-analysis
RCTs | De Nijs, 2004 ^265^
| Fracture Type
| Vertebral
Bianda, 2000 ^266^ | X
Henderson, 2001 ^267^ | X
Ringe, 2003 ^268^ | X
Sambrook, 2003 ^269^ | X
Van Cleemput, 1996 ^270^ | X

In one original study, the population comprised postmenopausal women with osteoporosis, and ^93^ the other study was composed of primarily male organ transplant recipients. ^261^ The bisphosphonate in both original studies was etidronate. Etidronate was compared with alfacalcidol in one study ^93^ and with calcidiol ^261^ in the other. There was no difference in fracture incidence between etidronate and either of the vitamin D preparations (Table 48). Data on fractures were collected as secondary outcomes in both studies; neither was powered to detect differences in fracture rates across study arms.

Table 48 Fractures with etidronate relative to vitamin D, by vitamin D preparation

Author, year | Study duration | Fracture type | Risk level | Number of fractures, etidronate | Number of fractures, vitamin D | Odds ratio (95% CI)
ALPHACALCIDIOL
Ishida, 2004 ^93^ | 24 months | Vertebral | High | 8/66 | 11/66 | 0.69 (0.26, 1.83)
CALCIDIOL
Garcia-Delgado, 1997 ^261^ | 18 months | Vertebral | High | 3/14 | 0/13 | 8.08 (0.76, 85.33)

##### Calcitonin vs. Estrogen

We identified one study ^93^ that compared the effect of calcitonin and estrogen on fracture incidence among postmenopausal women. There was no difference in fracture incidence between calcitonin and estrogen (Table 49). Fracture incidence was a secondary outcome in this study, and it was not powered to detect differences in fracture rates across study arms.

Table 49 Fractures with calcitonin relative to estrogen among postmenopausal women*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, calcitonin | Number of fractures, estrogen | Odds ratio (95% CI)
Ishida, 2004 ^93^ | 24 months | Vertebral | High | 8/66 | 7/66† | 1.16 (0.4, 3.39)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤≤2.5, or 3) study entry criteria require≥≥1 fracture, or 4) ≥≥50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history, and age not reported as entry criteria or in baseline characteristics of population.

† Estrogen combined with progesterone.

##### Calcitonin vs. Teriparatide (PTH)

We did not identify any studies that compared the effects of calcitonin and teriparatide on fracture risk.

##### Calcitonin vs. Vitamin D

We identified three studies ^93,^ ^141,^ ^261^ that compared the effects of calcitonin and vitamin D on fracture incidence. The study population in two studies was postmenopausal women at high ^93^ or low ^141^ risk for fracture and in the other study consisted predominantly of male organ transplant recipients at high risk for fracture. ^261^ One study demonstrated an increased risk of vertebral fracture with calcitonin relative to vitamin D. ^261^ Although the result was statistically significant, the confidence interval was very wide and the sample size was small. In the other studies, there was no difference in fracture incidence between groups (Table 50). Fracture incidence was a secondary outcome in each study; none were powered to detect differences in fracture rates across study arms.

Table 50 Fractures with calcitonin relative to vitamin D*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, calcitonin | Number of fractures, vitamin D | Odds ratio (95% CI)
Ishida, 2004 ^93^ | 24 months | Vertebral | High | 8/66 | 11/66 | 0.69 (0.26, 1.83)
Garcia-Delgado, 1997 ^261^ | 18 months | Vertebral | High | 4/13 | 0/13 | 9.71 (1.20, 78.42)
Ushiroyama T, 2001 ^141^ | 24 months | Vertebral | Low | 0/49 | 0/50 | NC

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤≤-2.5, or 3) study entry criteria require≥≥1 fracture, or 4) ≥≥50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤≤ 1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history, and age not reported as entry criteria or in baseline characteristics of population.

NC=not calculable.

##### Calcium vs. Vitamin D

We identified one RCT ^65^ that describes the number of fractures among subjects treated with calcium relative to vitamin D (Table 51). The study population was postmenopausal women with prior osteoporotic fractures at high risk for fracture. Fracture was the primary outcome for this study. There were no statistically significant differences in the risk of fracture for calcium relative to vitamin D for any type of fracture (Table 51).

Table 51 Risk of fracture for calcium, relative to vitamin D, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, calcium | Number of fractures, vitamin D† | Odds ratio (95% CI)
ALL FRACTURES
Grant, 2005 ^65^ | 62 months | New fractures | High | 189/1311 | 212/1343 | 0.90 (0.73, 1.11)
VERTEBRAL FRACTURES
Grant, 2005 ^65^ | 62 months | Clinical vertebral fractures | High | 3/1311 | 4/1343 | 0.77 (0.17, 3.39)
HIP
Grant, 2005 ^65^ | 62 months | Proximal femur fracture | High | 49/1311 | 47/1343 | 1.07 (0.71, 1.60)
WRIST
Grant, 2005 ^65^ | 62 months | Distal forearm fracture | High | 33/1311 | 33/1343 | 1.02 (0.63, 1.67)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤≤-2.5, or 3) study entry criteria require ≥≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history and age not reported as entry criteria or in baseline characteristics of population.

† Control group.

##### Estrogen vs. Vitamin D

We identified one RCT ^93^ that described the number of fractures among subjects treated with estrogen relative to vitamin D (Table 52). The study population in this study was postmenopausal women with intermediate risk for fracture. Fracture was a secondary outcome for this study. There was no statistically significant difference in the risk of fracture for estrogen relative to vitamin D for vertebral fractures (Table 52). However, the study was not powered to detect such differences.

Table 52 Risk of fracture for estrogen, relative to vitamin D, by fracture group*

Author, year | Study duration | Type of fracture | Risk level | Number of fractures, estrogen | Number of fractures, vitamin D† | Odds ratio (95% CI)
VERTEBRAL
Ishida, 2004 ^93^ | 24 months | Vertebral | High | 7/66† | 11/66 | 0.6 (0.22, 1.62)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤≤-2.5, or 3) study entry criteria require≥≥1 fracture, or 4) ≥≥50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history, and age not reported as entry criteria or in baseline characteristics of population.

† Estrogen plus medroxyprogesterone.

##### Estrogen vs. Teriparatide

We did not identify any studies that compared the effects of estrogen and teriparatide on fracture risk.

##### SERM vs. Estrogen

We identified one study ^166^ that compared the effects of raloxifene and estrogen on fracture incidence among postmenopausal women. There was no difference in fracture incidence between these groups (Table 53). Data on fracture incidence were collected as adverse events. This study was not powered to detect differences in fracture rates between study arms.

Table 53 Fractures with raloxifene, relative to estrogen, among postmenopausal women*

Author, year | Study duration | Fracture type | Risk level | Number of fractures, etidronate | Number of fractures, estrogen | Odds ratio (95% CI)
Reid, 2004 ^166^ | 36 months | Vertebral | Intermediate | 4/193† | 1/102 | 1.9 (0.03, 12.22)

* High-risk: 1) transplant population, or 2) study entry criteria require T score ≤-2.5, or 3) study entry criteria require≥1 fracture, or 4) ≥ 50% population has 1 or more fractures at baseline or 5) Significant neuromuscular impairment. Intermediate-risk: 1) study entry criteria require T score ≤1.5, or 2) 10–50% of population has one or more fracture at baseline, or 3) study population has chronic disease that is commonly treated with glucocorticoids or 4) in the absence of data on BMD or fractures, mean age of population > 62 years. Low-risk: 1) study entry criteria require T score ≤0.0, or 2) < 10% of population has BMD =8 g/cm2 at baseline, or 3) 0–10% of population has one or more fracture at baseline, or in the absence of data on BMD or fracture, mean age of population <62 years. Unknown risk: BMD, fracture history, and age not reported as entry criteria or in baseline characteristics of population.

† 60 and 150 mg dose groups combined.

## Key Question 2. How does fracture reduction resulting from treatments vary between individuals with different risks for fracture as determined by bone mineral density (borderline/low/severe), prior fractures (prevention vs. treatment), age, gender, glucocorticoid use, and other factors (e.g., community dwelling vs. institutionalized; vitamin D deficient vs. not)?

### Key Points

- Alendronate, etidronate, ibandronate, risedronate, teriparatide, and raloxifene reduce the risk of fractures among high risk groups including postmenopausal women with osteoporosis.
- Calcitonin has been demonstrated to reduce the risk of fracture among post-menopausal women.
- There are insufficient data to determine whether etidronate or ibandronate prevent fractures among groups at intermediate or low risk for osteoporosis including postmenopausal women without osteoporosis or among men.
- There are insufficient data to determine whether alendronate prevents fractures among groups at low risk for osteoporosis including postmenopausal women without osteoporosis or among men.
- Raloxifene prevents fractures in postmenopausal women at low risk for fracture.
- The effect of estrogen on fracture prevention for women at low risk is uncertain.
- Calcitonin, risedronate and teriparatide reduce the risk of fracture among men.
- Among subjects treated with glucocorticoids, fracture risk reduction was demonstrated for risedronate and alendronate.
- There is good evidence that tamoxifen does not prevent fractures among women at risk for breast cancer.
- Reduction in fracture risk for subjects treated with alendronate, risedronate, or vitamin D has been demonstrated in populations at increased risk for fracture due to conditions that increase the risk of falling, including stroke with hemiplegia, Alzheimer's disease, and Parkinson's.
- There are limited and inconclusive data on the effect of agents for the prevention and treatment of osteoporosis on transplant recipients and patients treated with chronic corticosteroids.

### Detailed Analyses

#### Fracture risk

Among the 24 meta-analyses reviewed for this report, six performed analyses that evaluated the effect of therapy for different groupings of fracture risk. ^39,^ ^41,^ ^43,^ ^47,^ ^51,^ ^162^ The criteria used to define risk groups for these studies overlapped but were not identical. Likewise, they overlapped with but were not identical to the risk groups defined for this report, which are as follows:

High-risk:

1) transplant population, or
2) study entry criteria require T score ≤ -2.5, or
3) study entry criteria require≥1 fracture, or
4) ≥50% of population has 1 or more fractures at baseline, or
5) Significant neuromuscular impairment

Intermediate-risk:

1) study entry criteria require T score ≤1.5, or
2) 10–49.99% of population has one or more fracture at baseline, or
3) study population has chronic disease that is commonly treated with glucocorticoids, or
4) in the absence of data on BMD or fractures, mean age of population ≥60 years.

Low-risk:

1) study entry criteria require T score ≤0.0, or
2) < 10% of population has BMD =8 g/cm2 at baseline, or
3) < 10% of population has one or more fracture at baseline, or
4) in the absence of data on BMD or fracture, mean age of population <60 years.

The risk groups defined in each of the meta-analyses were each categorized into the best fitting risk group for this report. The criteria used to define risk groups in each of the meta-analyses and how they fit into the risk groups defined for this report are detailed in Table 54. The risk estimates from each meta-analysis, by the risk groups defined for this report, are displayed in Table 55. The risk categories for subgroups detailed in the Women's Health Initiative ^163^ are also detailed. Among the three studies that contributed data to the pooled risk estimate of vertebral fractures for ibandronate that was calculated for this report (Figure 10), all were among high risk subjects. We assigned a high risk designation to the pooled study population. Among the four studies that contributed data to the pooled risk estimate of vertebral fractures for pamidronate that was calculated for this report (Figure 11), three were among high risk subjects and two were among intermediate risk subjects. We assigned a high risk designation to the pooled study population.

Table 54 Risk groups from published meta-analyses and from the Women's Health Initiative

Risk groups in other reports | Risk groups for this report
Author | High | Intermediate | Low
Avenell ^51^
Not selected for prior fracture | | X
Selected for prior fracture | X
Cauley (WHI) ^163^
Age at screening 50–59 | | | X
Age at screening 60–69 | | X
History of fracture | X
No history of fracture‡ | | X
Cranney ^39,^ ^41^ *
Prevention | | | X
Treatment | | X
Papapoulos ^43^
T-score ≤2.0 or vertebral fracture | | X
T-score ≤2.5 or vertebral fracture | X
Stevenson ^47^ †
Not selected for low BMD | | | X
Osteopenia | | | X
Elderly women not selected for BMD | | X
Osteoporosis | | X
Severe Osteoporosis | X
Torgerson ^162^
Women <60 | | | X
Women ≥60 | | X

* Cranney: ‘treatment trial’ population has T-score < -2 SD and/or baseline prevalence of fracture is >20% and/or average age is >62; ‘prevention trial’ population has T-score ≥ -2 SD and/or baseline prevalence of fracture is ≤20% and/or average age is ≤62.

† Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

‡ Classified as intermediate based on no fracture and mean age of overall population, which was 63.

Table 55 Risk of developing fracture for populations with more severe osteoporosis or osteopenia, by fracture risk, drug, and fracture type

| Fracture risk
| High | Intermediate | Low
Author, year | OR (95% CI)
Alendronate
Vertebral Fractures
Cranney, 2002 ^39^ | | 0.53 | 0.45
| | (0.43, 0.65) | (0.06, 3.15)
Stevenson, 2005 ^47^ | 0.53 | 0.60
| (0.42, 0.67) | (0.46, 0.80)
Non-Vertebral Fractures
Cranney, 2002 ^39^ | | 0.49 | 0.79*
| | (0.36, 0.67) | (0.28, 2.24)
Stevenson, 2005 ^47^ | 0.81 | 0.74\|
| (0.66, 0.98) | (0.52, 1.06)
Hip Fractures
Papapoulos, 2004 ^43^ | 0.45 | 0.56
| (0.28, 0.71) | (0.36, 0.84)
Stevenson, 2005 ^47^ | 0.46 | 0.68
| (0.23, 0.91) | (0.30, 1.54)
Wrist Fractures
Stevenson, 2005 ^47^ | 0.48 | 0.67
| (0.31, 0.75) | (0.19, 2.32)
Etidronate
Vertebral Fractures
Cranney, 2001 ^41^ | | 0.59 | 0.61
| | (0.38, 0.94) | (0.29, 1.26)
Stevenson, 2005 ^47^ | 0.43
| (0.20, 0.91)
Non-vertebral Fracture
Cranney, 2001 ^41^ | | 0.75
| | (0.34, 1.70)
Hip Fracture
Stevenson, 2005 ^47^ | 0.50
| (0.05, 5.34)
Ibandronate
Vertebral Fractures
Current report, Figure 10 | 0.70
| (0.54, 0.91)
Pamidronate
Vertebral Fractures
Current report, Figure 11 | 0.52
| (0.21, 1.24)
Risedronate
Vertebral Fractures
Stevenson, 2005 ^47^ | 0.62
| (0.50, 0.77)
Non-vertebral Fractures
Stevenson, 2005 ^47^ | 0.67
| (0.50, 0.90)
Hip Fracture
Stevenson, 2005 ^47^ | 0.66 | 0.60
| (0.48, 0.89) | (0.42, 0.88)
Wrist Fracture
Stevenson, 2005 ^47^ | 0.68
| (0.43, 1.08)
Estrogen
Vertebral Fractures
Stevenson, 2005 ^47^ | 0.58 | | 2.05
| (0.26, 1.30) | | (0.71, 5.97)
Non-vertebral Fractures
Stevenson, 2005 ^47^ | 0.67 | 1.17 | 0.86
| (0.12, 3.93) | (0.41, 3.28) | (0.72, 1.02)
Torgerson, 2001 ^162^ | | 0.88 | 0.67
| | (0.71, 1.08) | (0.46, 0.98)
Hip Fracture
Cauley, 2003 ^163^ † | | 0.76‡ | 0.17‡
| | (0.41, 1.39) | (0.02, 1.43)
Cauley, 2003 ^163^ † | 0.77§ | 0.52§
| (0.48, 1.22) | (0.28, 0.98)
Stevenson, 2005 ^47^ | | | 0.74
| | | (0.53, 1.03)
Wrist
Stevenson, 2005 ^47^ | | | 0.95
| | | (0.58, 1.53)
Teriparatide
Vertebral Fractures
Stevenson, 2005 ^47^ | 0.35
| (0.22, 0.55)
Non-vertebral Fractures
Stevenson, 2005 ^47^ | 0.65
| (0.43, 0.98)
Stevenson, 2005 ^47^ | 0.50
| (0.09, 2.73)
Wrist
Stevenson, 2005 ^47^ | 0.54
| (0.22, 1.35)
Humerus
Stevenson, 2005 ^47^ | 0.80
| (0.22, 2.98)
Raloxifene
Vertebral Fractures
Stevenson, 2005 ^47^ | 0.69 | | 0.53
| (0.56, 0.86) | | (0.35, 0.79)
Non-vertebral Fractures
Stevenson, 2005 ^47^ | 0.92
| (0.79, 1.07)
Hip Fracture
Stevenson, 2005 ^47^ | 1.12
| (0.65, 1.95)
Wrist Fracture
Stevenson, 2005 ^47^ | 0.89
| (0.68, 1.15)
Vitamin D
Vertebral Fractures
Avenell, 2005 ^51^ | 3.97 | 0.96\|
| (0.44, 35.45) | (0.42, 2.21)
Stevenson, 2005 ^47^ | 1.02 | 4.44
| (0.44, 2.32) | (0.50, 39.03)
Non-vertebral Fractures
Avenell, 2005 ^51^ | | 0.40
| | (0.05, 3.08)
Stevenson, 2005 ^47^ | | 0.46 | 0.86
| | (0.17, 1.27) | (0.72, 1.02)
Hip Fracture
Avenell, 2005 ^51^ | 1.08 | 1.20
| (0.72, 1.62) | (0.98, 1.47)

* Risk estimate based on single study.

† RCT comparing estrogen plus progestin, Hazards ratios reported in study.

‡ Based on age strata. See Table 54.

§ Based on history of fracture. See table 54.

Figure 10. Pooled risk of vertebral fractures for ibandronate relative to placebo or control

Table 55 compares the effects of agents on various risk groups. In some instances, pooled estimate for fracture risk of the population with a higher risk for fracture reached statistical significance when a pooled estimate of the population with less severe osteoporosis or osteopenia did not. Similarly, in some instances, the pooled estimate for fracture risk for the population with a higher fracture risk was higher than the estimate for the population with lower risk. However, in all instances the point estimates for the groups with the higher fracture risk fell within the 95% confidence intervals for the estimates for the group with lower fracture risk.

Three of the six meta-analyses that reported fracture risk according to risk groups included a risk group that could be categorized as “low risk” according to our criteria. ^41,^ ^47,^ ^162^ The Women's Health Initiative also reported fracture rates by risk groups. ^163^ The meta-analyses report pooled risk estimates among low risk populations for bisphosphonates, estrogen, raloxifene and vitamin D. Among the bisphosponates alendronate and etidronate, no significant risk reduction for fracture relative to placebo was demonstrated for low risk subjects in one meta-analysis. ^39^ For estrogen, no significant reductions in risk for vertebral or wrist fractures relative to placebo were reported for low risk subjects in one meta-analysis. ^47^ The risk of non-vertebral fractures for estrogen relative to placebo for low risk subjects was significantly reduced in one meta-analysis; ^162^ in another it was reduced, but not significantly. ^47^ For raloxifene, a significant reduction in risk for vertebral fractures relative to placebo was reported for low risk subjects in one meta-analysis. ^47^ There was no significant risk reduction for low risk subjects treated wih vitamin D relative to placebo in one meta-analysis. ^47^ The Women's Health Initiative evaluated risk of fracture for a number risk categories and did not find any significant differences in fracture risk across the different categories for hip ^163,^ ^165^ or total ^163^ fractures. In addition to history of fracture and age, both of which fit into the classification scheme used for this analysis (Table 55), the WHI also assessed fracture risk based on a composite fracture risk score and found no difference in risk across categories for hip or total fractures. Two additional RCTs in low-risk groups were published after these meta-analyses. In one trial ^141^ none of 49 calcitonin users had fractures at 24 months, compared to two of 52 control subjects. Another RCT among women at increased risk for breast cancer (but not selected for fracture risk) showed no difference in fractures between raloxifene and tamoxifen at 60 months. ^256^

#### Special Populations

Post-menopausal women, not classified into risk groups: An additional meta-analysis ^45^ that evaluated the effect of calcitonin relative to placebo was restricted to post-menopausal women, but did not provide other information to allow classification into one of the risk categories above. This meta-analysis reported a reduced risk of vertebral fractures with calcitonin relative to placebo (RR 0.46, 95% CI 0.25, 0.87). The risk of non-vertebral fractures was not significantly reduced with calcitonin relative to placebo (RR 0.52, 95% CI 0.22, 1.23).

Men: Few studies assessed the effect of agents to reduce fracture risk among men. Among nine studies that included men, ^65,^ ^92,^ ^123^ – ^125,^ ^140,^ ^142,^ ^195,^ ^196^ three demonstrated a reduction in fracture risk: one for total fractures with teriparatide, ^196^ one for hip fractures with risedronate, ^124^ and one for vertebral fractures with calcitonin. ^142^ Among the remaining studies, only one had sufficient sample size to assess the effect of agents on fracture. ^65^ In this study, which included men and women, there was no reduction in the rate of fractures for calcium relative to placebo; subgroup analyses found no difference in risk among men and women.

Breast cancer: We identified one large RCT ^204^ that evaluated the effect of tamoxifen relative to placebo on fracture risk among women older than 60 or women aged 35–59 with increased risk for breast cancer. There was no statistical difference in fracture risk between tamoxifen and placebo, for any type of fracture (Table 27).

Differences in fracture risk due to BMD-lowering medications or conditions. Eighteen RCTs were performed in special populations with increased risk for fractures as a result of medications or diseases that reduce BMD. There were 13 studies with populations at increased risk for fractures due to medications that decrease BMD: eight were performed among recipients of solid organ transplants; ^107,^ ^110^ – ^112,^ ^114,^ ^143,^ ^213,^ ^261^ two among bone marrow transplant recipients; ^113,^ ^256^ one among subjects with asthma; ^123^ and two among patients undergoing chemotherapy for lymphoma ^109^ and breast cancer. ^122^ Among 24 comparisons between drug and placebo or between two drugs, two demonstrated a significant difference in fracture risk for one study arm compared with another, although both have very wide 95% confidence intervals. In one, the risk of vertebral fracture was reduced for pamidronate relative to placebo (OR 0.14, 95% CI 0.03, 0.72) among patients receiving chemotherapy for lymphoma. ^109^ In the other, the risk of vertebral fracture for calcitonin relative to calcidiol was 9.71 (95% CI 1.2, 78.42) among lung transplant recipients. ^261^ Among all 23 studies, fracture data were collected as secondary outcomes or adverse events; none were powered to detect differences in fracture rates across study arms.

There were four studies among populations at increased risk for fracture due to a disease that is associated with low BMD: two among subjects with primary biliary cirrhosis; ^71,^ ^252^ one among subjects with leoprosy; ^125^ and one among subjects with inflammatory bowel disease in remission. ^120^ Among six comparisons between drug and placebo or between two drugs, one demonstrated a significant difference in fracture risk for one study arm compared with another. In this study, ^120^ the risk of vertebral fracture among subjects with inflammatory bowel disease in remission was reduced for risedronate relative to placebo (OR 0.3, 95% CI 0.11, 0.84). There were no significant differences in risk between alendronate and placebo or risedronate and placebo in studies of subjects with primary biliary cirrhosis or leprosy. Fracture was a secondary outcome in all of these studies and none were powered to detect differences in fracture rates across study arms.

Differences in Fracture Risk due to Increased Risk for Falls. There were six studies among populations at increased risk for fracture due to conditions that increase the risk of falling: three among subjects with stroke and hemiplegia; ^119,^ ^124,^ ^214^ one among subjects with Alzheimer's disease; ^118^ one among subjects with a recent hip fracture; ^89^ and one among subjects with Parkinson's disease in remission. ^72^ Across these studies, there were seven comparisons between alendronate, etidronate, risedronate, or vitamin D and placebo, six of which demonstrated significant reductions in fracture risk for the agent relative to placebo (Table 56). Fracture was the primary outcome in three of these studies and a secondary outcome in two. ^72,^ ^214^ All but two ^72,^ ^214^ had sufficient sample size to detect differences in fracture risk across arms, although one of these two studies demonstrated a significant difference in risk across arms. ^214^

Table 56 Risk of fracture among populations at increased risk for falling, by drug

Author, year | Study duration | Type of fracture | Number of fractures, agent | Number of fractures, placebo or control | Odds ratio (95% CI)
Alendronate
Sato, 2006 ^72^ | 48 months | Hip fracture | 4/131 | 14/129 | 0.3 (0.12, 0.78)
Etidronate
Sato, 2004 ^89^ | 3 months | Hip fracture | 0/36 | 0/37 | NA
Risedronate
Sato, 2005 ^119^ | 12 months | Hip fracture | 1/172 | 7/173 | 0.22 (0.05, 0.88)
Sato, 2005 ^118^ | 18 months | Hip fracture | 5/231 | 19/230 | 0.29 (0.13, 0.66)
Sato, 2005 ^118^ | 18 months | Nonvertebral fracture | 8/231 | 29/230 | 0.29 (0.15, 0.57)
Sato, 2005 ^124^ | 18 months | Hip fracture | 2/134 | 10/133 | 0.25 (0.08, 0.78)
Vitamin D
Sato, 2005 ^214^ | 24 months | Hip fractures | 0/24 | 4/24 | 0.12 (0.02, 0.90)

#### Glucocorticoid-induced osteoporosis

Bisphosphonates: We identified one systematic review ^271^ and six studies published subsequent to the review ^92,^ ^94,^ ^136,^ ^263,^ ^272,^ ^273^ that evaluated the effect of bisphosphonates on fracture incidence among subjects treated with glucocorticoids. The systematic review identified nine studies ^137,^ ^274^ – ^281^ published before 1999 that reported fracture data, although not as the primary outcome (Table 57). The authors of the systematic review report that six of the studies ^137,^ ^274^ – ^277,^ ^280^ analyzed the difference between treatment and control group with regard to fracture risk; three found a trend in reduced fracture rate ^137,^ ^274,^ ^276^ and one demonstrated a 10.1% reduction in vertebral fractures among patients treated with risedronate compared with control. ^137^

Among the studies published after the systematic review, three demonstrated significant reductions in the risk of fracture for bisphosphonates relative to placebo and three did not. One study ^273^ that compared risedronate and placebo demonstrated a statistically significant reduction in the absolute risk and relative risk of incident radiographic vertebral fractures (11% and 70%, respectively) after 1 year. This study included data from the Cohen trial, ^137^ which was included in the systematic review. Another, ^272^ which compared alendronate and placebo, demonstrated a significant reduction in the risk of incident radiographic vertebral fractures (0.7% with alendronate versus 6.8% with placebo; p < 0.05). The third trial with significant results ^136^ compared two different daily doses of risedronate with placebo. A significant reduction in the incidence of vertebral fractures of 70% was found for the combined risedronate groups. In the remaining three trials, there was no significant difference in fracture risk between etidronate and control, ^92,^ ^94^ calcium and control, ^92^ or calcium and etidronate. ^92^

Calcitonin: We identified one meta-analysis ^42^ that evaluated the effect of calcitonin relative to placebo for the prevention and treatment of glucocorticoid-induced osteoporosis. Among four trials and a total of 256 subjects, the pooled risk for vertebral fractures for calcitonin relative to placebo was 0.71 (95% CI, 0.26, 1.89). Among four trials and a total of 208 subjects, the pooled risk for non-vertebral fractures was 0.52 (95% CI 0.14, 1.96).

#### Other risk groups

We did not identify any studies that evaluated the effect of treatments for osteoporosis for different age groups, levels of vitamin D deficiency, or residence in the community compared with residence in a nursing home.

## Key Question 3. What are the adherence to and persistence with medications for the treatment and prevention of osteoporosis, the factors that affect adherence and persistence, and the effects of adherence and persistence on the risk of fractures?

### Key Points

- Only 10 fracture trials reported rates of adherence to therapy. Five trials of calcium reported high rates of non-adherence. In studies that defined “adherence” as taking at least 80% of pills, from 32% to 78% of subjects were adherent. In two studies of daily oral bisphosphonates, more than 80% of patients took at least 70% of the drug. The other three trials reported high rates of adherence with weekly risedronate therapy.
- There is evidence from 10 observational studies that adherence to therapy with alendronate, etidronate, risedronate, calcitonin, HRT, raloxifene, and calcium and vitamin D is poor in many postmenopausal women with osteoporosis.
- There is evidence from one observational study that adherence to therapy with alendronate and risedronate is poor in many chronic glucocorticoid users.
- There is evidence from 12 observational studies that persistence with therapy with alendronate, etidronate, risedronate, calcitonin, HRT, raloxifene, and calcium and vitamin D is poor in many men and postmenopausal women with osteoporosis.
- Based on evidence from observational studies, factors that affect adherence and persistence include side effects of medications, absence of symptoms related to the underlying disease, co-morbid conditions, ethnicity, socioeconomic status, and dosing regimens.
- In four observational studies comparing weekly and daily bisphosphonates, weekly users had higher persistence and adherence rates.
- There is evidence from RCTs and observational studies that postmenopausal women who are non-adherent to treatment with alendronate, risedronate, HRT, calcium, or calcitonin have an increased risk of fracture compared with women who are adherent to therapy.
- There is evidence from one observational study that postmenopausal women with osteoporosis who are non-persistent with alendronate and risedronate therapy have an increased risk of fracture compared with women persistent with these medications.

### Detailed Analyses

#### Effect of adherence and persistence of medications for osteoporosis on fractures in RCTs

Among the RCTs included in this report that assessed the effect of agents on the prevention of fractures, 27 reported that they measured subject adherence to therapy. However, among these studies, only 10 reported rates of adherence to therapy. ^63^ – ^65,^ ^127,^ ^128,^ ^206,^ ^207,^ ^262,^ ^282,^ ^283^ Of these, only five included an analysis of outcomes that considered adherence to therapy. ^63,^ ^64,^ ^206,^ ^207,^ ^282^

Five RCTs ^63^ – ^65,^ ^206,^ ^207^ reported high rates of non-adherence with calcium. In one study, ^206^ 57% of the subjects took at least 80% of their calcium pills. Reduced fracture incidence was seen in the calcium compared with the placebo groups (10.2% vs 15.4%; hazard ratio, 0.66; 95% CI 0.45–0.97). In a second study, ^63^ 59% of subjects took at least 80% of their calcium and vitamin D pills. These subjects had a 29% reduction in hip fractures compared with placebo groups (hazard ratio 0.71; 95% CI 0.52 – 0.97). In another study, ^64^ 12-month adherence rates were only 63% among women participating in a trial of calcium plus vitamin D vs. placebo. The definition of adherence used in this study was not described, and adherence was calculated only for women known to be alive at the 12-month timepoint. There was no difference in fracture incidence among women who adhered to treatment compared with placebo. In another study, ^207^ 32% of subjects had at least one 6-month period of compliance less than 60%. When these non-adherent patients were excluded from the analysis, there was no significant difference in hip or vetebral fracture risk among women taking calcium compared with those taking placebo. In another study, ^65^ 78% of subjects took at least 80% of their calcium pills. An analysis of adherent subjects was not performed.

Five RCTs reported rates of adherence with bisphosphonate treatments. ^127,^ ^128,^ ^262,^ ^282,^ ^283^ We identified a study that reported rates of adherence with alendronate. ^282^ In this study, 81% of patients took at least 70% of their study drug. Fracture risk was reported by stratifying patients into three categories based on their change in BMD over the course of the study. Adherent subjects taking alendronate who had a 0–4% decrease in lumbar spine BMD over the course of the study had a reduction of 60% in vertebral fracture risk compared with those taking placebo (OR 0.40 95% CI 0.16 – 0.99). Those who “gained” BMD (0% to 4%) during treatment had a reduction of risk of 51% (OR 0.49 95% CI 0.30 – 0.78). Those who lost more than 4% of BMD over the course of the study did not have a significant change in fracture risk. In a separate study, ^262^ rates of adherence were reported among patients randomized to either raloxifene or alendronate. Overall, 84.3% of subjects took at least 70% of their study medication, with no difference between treatment groups. An analysis of adherent subjects was not performed for this study.

We also identified three RCTs that reported high rates of adherence with weekly risedronate therapy. ^127,^ ^128,^ ^283^ One study ^128^ reported that 98% of subjects randomized to weekly risedronate or to placebo took at least 80% of their study medications. Another study ^283^ reported that 100% of subjects in the risedronate group and 99.3% taking placebo were adherent, defined as “receiving the study drug at the correct time and in the appropriate manner.” A third study reported that 98% of subjects were adherent with weekly risedronate therapy. ^127^ An analysis of adherent subjects was not performed for any of these three studies.

#### Effect of adherence and persistence of medications for osteoporosis on fractures in observational studies

We identified three observational studies ^284^ – ^286^ that assessed the effect of adherence or persistence on fracture risk (Table 58). Rates of fracture prevention in all three studies were shown to vary according to levels of adherence to therapy. Huybrechts and colleagues identified a cohort of 38,120 women with osteoporosis from a large US managed care database who were administered alendronate, risedronate, or hormone replacement therapy (HRT) over a 5-year period. ^286^ They found that three quarters of the women had low adherence, defined as a medication possession ratio (MPR) below 80% over the entire course of their follow-up. After adjusting for other known risk factors, low adherence was associated with a 17% increased risk of fracture. Low adherence was also associated with a 37% increase in all-cause hospitalization, and with higher average monthly costs for all medical services. Siris used two large US commercial claims databases to examine refill adherence (defined as MPR > 80%) among all women in a 5-year period who received a prescription for either alendronate or risedronate. ^285^ Adherence to medications was associated with a 25% relative reduction in risk for all osteoporotic fractures compared with noncompliant patients. Persistence with therapy (nonpersistence was defined as a refill gap of more than 30 days during the period of the study) was associated with a 29% reduction in the risk of nonvertebral fractures and a 45% reduction in the risk of hip fractures. Another study, which used data obtained from the health services databases of Saskatchewan, Canada, found that among 11,249 women who were treated with alendronate, risedronate, etidronate ±calcium, calcitonin, or HRT for osteoporosis, those with a MPR ≥ 80% experienced a 16% lower fracture rate. ^284^

Table 58 Effect of adherence to and persistence with osteoporosis medications on fractures

Author, year | Sample size | Study duration | Medications | Effect of adherence or persistence
Huybrechts, 2006 ^286^ | 38,120 | 5 years | Alendronate | 17% increase in fracture rate with low adherence.
| | | Risedronate
| | | HRT
Siris, 2006 ^285^ | 35,537 | 24 months | Alendronate | Relative risk reduction 25% for all osteoporotic fractures in refill adherent patients; 29% risk reduction for non-vertebral fractures, 45% risk reduction for hip fractures in persistent patients
| | | Risedronate
Caro,2004 ^284^ | 11,249 | 5 years | Alendronate | 16% decrease in fracture rate in patients with good adherence (MPR>80%)
| | | Etidronate ± calcium
| | | Risedronate
| | | Calcitonin
| | | HRT

#### Rates of adherence and persistence-medications to treat or prevent osteoporosis

We identified 18 observational studies that reported rates of adherence (Table 59) or persistence (Table 60) for medications used to treat or prevent osteoporosis.

Table 59 Rates of adherence with osteoporosis medications

Author, year | Sample size | Study duration | Medications | Adherence*
Caro* 2004 ^284^ | 11,249 | 5 years | Alendronate | 49.4% adherence over course of study; mean follow-up 2 years
| | | Etidronate ± calcium
| | | Risedronate
| | | Calcitonin
| | | HRT
Faulkner, 1998 ^287^ † | 28,718 | 1 year | HRT | 46% adherence at 1 year
Siris,* 2006 ^285^ | 35,537 | 2 year | Alendronate | 43% adherence at 2 years
| | | Risedronate
Weycker*, 2006 ^288^ | 18,882 | 3 years | Alendronate | 53% at 3 months
| | | Risedronate | 30% at 1 year
| | | Calcitonin | 26% at 3 years
| | | HRT
| | | Raloxifene
Huybrechts* 2006 ^286^ | 38,120 | 5 years | Alendronate | 25% adherence over course of study; mean follow-up 1.7 years
| | | Risedronate
| | | HRT
deLusignan* 2006 ^289^ | 1,286 | 1 year | Alendronate | 45% adherence at 1 year
| | | Risedronate
Unson* 2006 ^290^ | 107 | 6 month | Calcium + Vitamin D | 81% adherence at 6 months for HRT/placebo; 78% adherence at 6 months for calcium + vitamin D
| | | plus
| | | Estrogen or placebo
Downey‡ 2006 ^291^ | 10,566 | 1 year | Alendronate | 61% mean adherence rate for alendronate; 58% mean adherence rate for risedronate; 54% mean adherence rate for raloxifene
| | | Risedronate
| | | Raloxifene
Curtis ‡ 2006 ^292^ | 1,158 | 3 year | Alendronate | Mean adherence rate 72% alendronate, 74% risedronate; study of chronic glucocorticoid users
| | | Risedronate
Turbi* 2003 ^293^ | 902 | 12 months | Raloxifene | 95% adherence in raloxifene group; 91% adherence in alendronate at 1 year
| | | Alendronate

* Defined by attaining specific MPR of 80%.

† Defined by attaining specific MPR of 75%.

‡ Defined as mean MPR attained by individual patients over the study period.

Table 60 Rates of non-persistence with osteoporosis medications

Author, year | Sample size | Study duration | Medications | Percent discontinuing medication
Caro, 2004 ^284^ | 11,249 | 5 years | Alendronate | 60% at 5 years
| | | Etidronate ± calcium
| | | Risedronate
| | | Calcitonin
| | | HRT
Downey, 2006 ^291^ | 10,566 | 1 year | Alendronate | 79% discontinuation at 1 year with alendronate; 81% discontinuation at 1 year with risedronate; 84% discontinuation with raloxifene
| | | Risedronate
| | | Raloxifene
Tosteson, 2003 ^296^ | 956 | 4–12 months | HRT | 26% discontinuation in HRT; 19% discontinuation raloxifene; 19% alendronate, all at mean of 7 months
| | | Raloxifene
| | | Alendronate
Rossini, 2006 ^297^ | 9,851 | 11–18 months | Calcium + Vitamin D | 19.1% discontinuation at mean of 14 months
| | | HRT
| | | Raloxifene
| | | Risedronate
| | | Clodronate
| | | Alendronate
Segal, 2003 ^298^ | 178 | 6 months | Raloxifene | 23% discontinuation rate at 6 months
| | | Alendronate
Turbi, 2003 ^293^ | 902 | 1 year | Raloxifene | 26% discontinuation in alendronate group; 16% discontinuation in raloxifene group at 1 year
| | | Alendronate
Buist, 2000 ^299^ | 6,459 | 12 months | Alendronate | 2.2% discontinuation at 1 month
| | | Placebo | 4.8% at 3 months
| | | | 11.1% at 12 months
Weycker, 2006 ^288^ | 18,882 | 3 years | Alendronate | 47% discontinuation at 1 year;
| | | Risedronate | 77% discontinuation at 3 year
| | | Calcitonin
| | | HRT
| | | Raloxifene
Lo, 2006 ^300^ | 13,455 | 1 year | Alendronate | 50% discontinuation at 1 year
Steel, 2003 ^301^ | 838 | 5 years | HRT | 34% discontinuation at 2 years
| | | | 39% discontinuation at 5 years
Papaioannou, 2003 ^302^ | 1,967 | | Etidronate | 14% discontinuation at 1 year
| | | Alendronate | 23% discontinuation at 2 years
| | | HRT | 30% discontinuation at 3 years,
Solomon, 2005 ^303^ | 40,042 | 5 years | Alendronate | 45.2% discontinuation at 1 year
| | | Risedronate | 52.1% discontinuation at 5 years
| | | Calcitonin
| | | Raloxifene
| | | HRT

#### Adherence

Ten studies assessed adherence to osteoporosis medications. ^284^ – ^293^ We identified eight studies that examined adherence among cohorts of patients identified using large retrospective clinical databases. A Canadian health services database was used to examine adherence of all women during a 5-year period who were diagnosed with osteoporosis and who were prescribed at least one treatment medication (including bisphosphonates, HRT, or calcitonin). ^284^ In this study, fewer than 50% of patients had a MPR greater than 80% over the 5-year period. Another study examined data from 49 US health plans to identify 18,882 women with osteoporosis who initiated therapy with a bisphosphonate, calcitonin, raloxifene, or estrogen during a 5-year period. ^288^ Adherence failure in this study was defined as a MPR less than 80%. Overall, the investigators found that the rate of adherence failure was 47% at 3 months, 70% at 1 year, and 77% at 3 years. In another study, refill compliance (defined as MPR > 80%) among all women enrolled in one of two large US commercial insurance plans and receiving a prescription for either alendronate or risedronate ^285^ was 43% over 5 years. ^285^

A large US managed care database was used to identify 38,120 women with osteoporosis who were treated with alendronate, risedronate, or HRT over a 5-year period. ^286^ Among these women, 75% had an MPR below 80% over their entire follow-up period. Another study examined a general United Kingdom (UK) practice computer database of 97,992 women to identify 1,286 women who received a prescription for either alendronate or risedronate in a 1-year period. ^289^ They found that 45% of women were adherent at 1 year (defined as a MPR > 80%). Finally, 10,566 women from a US national managed care administrative claims database who were prescribed risedronate, alendronate, or raloxifene were followed over a 6-month period. ^291^ They identified the MPR for each individual patient and found a mean adherence rate of 61% for alendronate, 58% for risedronate, and 54% for raloxifene.

A single study reported adherence rates for one individual drug. Using a large US prescription claims database to identify 28,718 women initiated on HRT, Faulkner and colleagues found that 55% were non-compliant with therapy (defined as MPR < 75%) at 1 year. ^287^

Rates of adherence to osteoporosis prevention therapies were also examined in a study of glucocorticoid users. A large US national managed care database was examined to identify 6,282 chronic glucocorticoid users who were prescribed alendronate or risedronate during a 3-year period. ^292^ The mean adherence rates were not statistically different between users of alendronate (72%) and risedronate (74%).

We also identified two studies that examined adherence rates in controlled clinical trials. In one study, women were randomized to either placebo plus calcium and vitamin D or HRT plus calcium and vitamin D. ^290^ Patients taking ≥80% of their pills were considered adherent. At 6 months, 81% of subjects were adherent to HRT/placebo, while 78% of subjects were adherent to calcium and vitamin D. Another study used a prospective non-randomized cohort to examine adherence among Spanish women who were treated with raloxifene or alendronate. ^293^ Overall, patients in the raloxifene group reported signficantly better adherence than did women in the alendronate group (95% vs. 91%); however, it should be noted that this study was sponsored and co-authored by the makers of raloxifene.

Poor adherence to treatment instructions has also been demonstrated in two studies. Hamilton and coworkers studied 219 UK patients attending an osteoporosis clinic to determine compliance with risedronate therapy. ^294^ Although all participants were given detailed oral instructions and a leaflet detailing the proper administration of risedronate, the investigators discovered using follow-up questionnaires that 26% of patients took their medication incorrectly, and 28% of these experienced adverse events. In a separate study, 10 inpatients and 30 outpatients were administered alendronate for osteoporosis. ^295^ Both inpatients and outpatients took the medication incorrectly: 37% of inpatients and 7% of outpatients received other medications with the alendronate, and 12% of inpatients did not sit upright after receiving alendronate. Thus, even when patients are technically taking their medications, improper techniques may inhibit absorption of the correct dose or may increase the likelihood of side-effects.

#### Persistence

We identified 12 studies that reported persistence rates for osteoporosis medications. ^284,^ ^288,^ ^291,^ ^293,^ ^296^ – ^303^ These studies are displayed in Table 60. Nine of these studies used large claims databases. One study used a database of all Medicare beneficiaries participating in a state-run drug benefits program to identify a cohort of patients who initiated treatment for osteoporosis. ^303^ Treatments included bisphosphonates, calcitonin, HRT, or raloxifene. The investigators found that after 1 year of therapy, 45% of subjects were no longer taking osteoporosis medications, a figure that increased to 52% of patients at 5 years. Another study that examined a prospective observational Canadian database, CANDOO, found that among men and women who initiated therapy with etidronate, alendronate (daily), or HRT in a 10.5-year time period, 86% were still taking any one of these three therapies at 1 year; 77% and 70% of patients continued therapy at 2 and 3 years, respectively. ^302^ Alendronate-treated patients were 40% more likely to discontinue therapy than were etidronate-treated patients. There were no differences in discontinuation rates between HRT and either alendronate or etidronate. In the study noted above by Weycker and coworkers, the rate of persistence failure among patients prescribed a bisphosphonate, calcitionin, HRT, or raloxifene was 47% at 1 year and 77% at 3 years. ^288^ In a separate study, there was a 79% 1-year discontinuation rate with alendronate, an 81% discontinuation rate with risedronate, and an 84% discontinuation rate with raloxifene. ^291^ A telephone survey of 956 women from the Kaiser Permanente Northern California database who initiated treatment with HRT, raloxifene, or alendronate over a 3-year period was conducted. ^296^ A mean of 7 months of treatment, 26% of subjects taking HRT had discontinued therapy, which was significantly higher than the proportion who discontinued raloxifene (19%) or alendronate (19%). A study by Caro and coworkers, 60% of subjects treated with a bisphosphonate, calcitonin, or HRT discontinued therapy within 5 years. ^284^ Rossini and coworkers identified 9,851 postmenopausal Italian women who were prescribed calcium + vitamin D, HRT, raloxifene, risedronate, clodronate, or alendronate for osteoporosis. ^297^ Using a follow-up questionnaire, the investigators found that 19.1% of subjects had discontinued their medications, at a mean follow-up time of 14 months.

Two studies used a large clinical database to assess the persistence rates of individual medications for osteoporosis. The Kaiser Permanente of Northern California database was examined to determine persistence rates among women prescribed weekly oral alendronate. ^300^ The 1-year discontinuation rate was 50%, although 1/3 of women discontinuing therapy restarted within 6 months. In a prospective cohort study of 6,282 UK women prescribed HRT for osteoporosis, approximately 34% of women discontinued HRT in the first 2 years of use. ^301^

Two smaller cohort studies have also examined rates of persistence with osteoporosis therapy. One study identified 178 consecutive patients prescribed either daily alendronate or raloxifene for osteoporosis. ^298^ They found that 23% of patients had discontinued therapy within 6 months. In the pharmaceutical company-sponsored prospective randomized cohort study (described above), 26% of subjects in the alendronate group and 16% of subjects in the raloxifene group discontinued therapy at 1 year. ^293^

One study examined rates of persistence in a controlled clinical trial. Among 6,459 postmenopausal women randomized to either alendronate or placebo in the FIT trial, ^299^ the 1-year overall discontinuation rate was 11%.

Several studies have revealed that the rate of discontinuation for osteoporosis therapies is highest during the first 2 years of treatment. In a study of women prescribed HRT for osteoporosis, 34% discontinued HRT in the first 2 years of use; however, after 2 years, the rates of further discontinuation were low. ^301^ In studies by Solomon ^303^ and Weycker, ^288^ rates of discontinuation and adherence failure were also greatest in the first 2 years following initiation of therapy.

#### Factors that affect adherence and persistence to osteoporosis medications

We identified 25 studies ^286,^ ^287,^ ^290,^ ^292,^ ^293,^ ^296^ – ^299,^ ^302,^ ^303,^ ^303^ – ^315^ that identified factors that may affect adherence or persistence with medications for osteoporosis: side effects, absence of symptoms, comorbid conditions, age, ethnicity, socioeconomic status, and dosing regimen.

#### Side effects of medications

We identified five studies that documented side effects as a contributing factor to non-persistence with medications. ^293,^ ^296^ – ^298,^ ^304^ In two separate non-randomized observational studies comparing raloxifene and alendronate, ^293,^ ^298^ the most frequent cause identified for medication discontinuation was medication side effects. Similarly, in the telephone survey of a cohort of women who had been started on HRT, raloxifene, or alendronate for osteopenia or osteoporosis, two-thirds of patients who had discontinued therapy cited side effects as the primary reason for discontinuance. ^296^

Fear of side effects can also affect adherence to osteoporosis medications. Questionnaires were used to assess reasons for medication discontinuation among women who had been prescribed calcium ± vitamin D, HRT, raloxifene, or bisphosphonates for osteoporosis. ^297^ Although 25% of women in the cohort listed side effects as the primary reason for medication discontinuation, 20% named fear of side effects as their motivation. Similarly, a questionnaire study of a US cohort of 816 women starting HRT revealed that women who were concerned about the side effects of HRT were 3.7 times more likely to discontinue therapy within 2 years than were women who did not express these concerns. ^304^

#### Absence of symptoms

We identified four studies that documented absence of symptoms as a reason for non-persistence with osteoporosis therapy. ^292,^ ^299,^ ^303,^ ^305^ Patients with osteoporosis who have not experienced an osteoporotic fracture do not suffer from symptoms of the disease and frequently are unaware of their diagnosis until bone densitometry is performed. Women who have not been shown documentation of their osteoporosis, or who have not experienced effects from their osteoporosis (i.e., fracture) may be less likely to persist with therapy. In a retrospective cohort study, a multivariate analysis found that a history of a fracture before or after initiation of osteoporosis therapy or a history of BMD testing before and after initiating therapy were both independently associated with increased persistence. ^303^ Similarly, a managed care database study of glucocorticoid users initiating therapy with bisphosphonates found that a lack of previous BMD testing was significantly associated with an increased risk of non-persistence. ^292^ In one focus group study of postmenopausal women who were educated about osteoporosis treatments and asked to choose a therapy, women who thought they were unlikely to sustain a fracture, or who perceived fracture outcomes as not severe were likely to choose no treatment for osteoporosis. ^305^ However, a history of previous fracture was not associated with study medicine discontinuation among participants in the FIT RCT. ^299^

#### Co-Morbid Conditions

Patients with multiple co-morbid conditions may also be less likely to adhere to osteoporosis therapy. We found two studies ^299,^ ^303^ that implicated co-morbid conditions in reduced persistence with osteoporosis therapy. Solomon and coworkers found that in their cohort, smaller numbers of comorbid conditions independently predicted increased persistence. ^303^ In a sub-analysis of adherence data from the FIT trial found that the strongest predictors of study medicine discontinuation were fair-to-poor self-rated health and the presence of four or more depressive symptoms. ^299^

#### Age

Findings on the effect of age on adherence to osteoporosis therapy varied. ^287,^ ^299,^ ^302,^ ^303^ Two studies implicated younger age in poorer compliance. In a retrospective cohort study of the CANDOO database, increasing age was an independent predictor of medication adherence. ^302^ In another retrospective cohort analysis, younger age was associated with non-compliance with HRT. ^287^ In contrast, Solomon and coworkers found that younger age independently predicted increased persistence, ^303^ no association between age and study medicine discontinuation was found in the FIT trial. ^299^

#### Ethnicity and Socioeconomic Status

We found four articles that studied ethnicity and socioeconomic status (SES) as factors that affect adherence and persistence to osteoporosis therapy. ^290,^ ^306^ – ^308^ Several aspects of SES, such as income and education level, may influence the likelihood that a patient will remain adherent to osteoporosis therapy. Additionally, ethnicity and cultural beliefs may also influence adherence. Unson and coworkers examined the influence of SES and ethnicity on medication adherence (calculated using MPR) in a placebo-controlled trial of calcium, vitamin D, and estrogen. ^290^ They demonstrated that minority participants and those with lower income and educational levels had lower adherence rates than white participants and those with higher SES.

Three studies have examined the role of SES in persistence with HRT therapy. A follow up study to the PEPI trial, which compared the effects of estrogen alone or in combination with progestin with placebo, ^316^ examined determinants of estrogen continuation after participation in the trial. ^306^ Education and non-white ethnicity predicted lower post-trial persistence with hormone use. Similarly, in a cross-sectional study of 50–70 year old women in Vermont, women of moderate to high income were three times more likely than those with low income to initate therapy with HRT. ^307^ A separate cross-sectional study of postmenopausal women in Turkey demonstrated that higher educational status was directly related to the likelihood that a patient will begin HRT, but is not related to discontinuation of HRT. ^308^

#### Dosing regimen

We identified eight articles that studied the frequency of medication dosing and non-adherence to and non-persistence with osteoporosis therapy. ^291,^ ^309^ – ^315^ In a national telephone survey of women taking bisphosphonates for osteoporosis in the UK, non-persistence with therapy was significantly associated with self-reported “difficulty taking medications because of too frequent dosing.” A complaint of too frequent dosing was associated with increased likelihood of discontinuation in both the daily and weekly bisphosphonate doses in this study. ^309^ We also identified two patient preference studies that reported a patient preference for less frequent dosing of medications. In one open-label trial of women taking daily alendronate who were switched to weekly alendronate, 96% of patients preferred the weekly dosage. ^310^ In another similar patient preference study, 86% of women preferred the once weekly dose of alendronate to the once daily regimen, and most patients also expressed that the once weekly dosing would allow them to achieve better long-term adherence (87.5% vs. 8.5%). ^311^

We also identified five studies that compared adherence or persistence rates between different dosing regimens. In the cohort study noted above by Downey, weekly bisphosphonate users had slightly higher 12-month adherence (63% vs. 54%) and persistence rates (22% vs. 19%) than did daily users. ^291^ Similarly, a study that used an administrative claims database from 30 US health plans revealed that weekly bisphosphonate users had a significantly higher mean MPR than did daily users (69% vs. 58%). ^312^ In that study, persistence rates were also higher among weekly bisphosphonate users (44% vs. 32%), and in multivariate analysis adjusting for other risk factors, dosing frequency was the strongest predictor of time to discontinuation. In a separate review of three UK databases, patients on weekly bisphosphonate regimens had a consistently higher mean MPR and longer persistence than did those taking daily bisphosphonates. ^313^ Another review of 211,319 patients in a US pharmacy database demonstrated that only about one third of patients receiving daily bisphosphonates, compared with 45% of weekly users, achieved adequate adherence, defined as MPR > 80%. ^314^

We found one open-label study that compared monthly ibandronate with weekly alendronate. ^315^ In that study, the investigators found that 6-month persistence rates were higher in the monthly ibandronate group (57% vs. 37%). It should be noted, however, that the trial was co-authored by the manufacturers of ibandronate, and that only the ibandronate group participated in a patient-support program, which may have influenced persistence rates.

#### Monitoring programs

Patient monitoring programs can also be used to identify at-risk patients who are non-adherent with their osteoporosis treatments. One approach to increased patient monitoring is to increase contact between health care providers and patients. This approach can be used not only to monitor adherence to therapy directly, but also to provide patients with additional opportunities to discuss questions or problems related to therapy. One study randomized 75 women with osteopenia on raloxifene to one of three groups: 1) no monitoring, 2) monitoring with three nurse visits to assess well being, record adverse events, and assist with medication problems (but not adherence), or 3) monitoring with both nurses visits and with assessment of markers of bone turnover. ^317^ They found that patients in both monitored groups increased cumulative adherence by 57% and persisted with therapy 25% longer than did non-monitored patients. In addition, adherence at 1 year was correlated with a significant improvement in hip BMD. The addition of marker measurements did not improve adherence or persistence compared with nurse monitoring alone.

In the future, computer monitoring may also be used to improve patient adherence with therapy. In the study detailed above, a computerized data extraction program was used to identify women in a population who are at risk for osteoporotic fractures and who should be targeted for osteoporosis therapy. They also used the program to calculate adherence to therapy. The authors noted that a program such as this could be used in the future to identify non-adherent patients. ^289^ However, in the United States, the use of such programs may be limited by privacy issues and compliance with HIPAA guidelines.

Non-adherence and non-persistence to osteoporosis therapies may severely reduce the effectiveness of these medications and may lead to unnecessary fractures and ultimately to an increase in the public health burden. Strategies to improve adherence should be investigated and implemented.

## Key Question 4. What are the short- and long-term harms (adverse effects) of the therapies, and do these vary by any specific subpopulations?

### Key Points

- Across a large body of randomized controlled trials, there were no differences in the rates of serious cardiac events among bisphosphonates, calcium, vitamin D, calcitonin, PTH, and placebo.
- A significant increase in the risk of atrial fibrillation for zoledronic acid relative to placebo has been reported in one large RCT but not in another (see addendum to executive summary); a trend toward increased risk for alendronate relative to placebo has been reported in a single large RCT.
- Relative to placebo, raloxifene had increased pooled risk for pulmonary embolism (PE), thromboembolic events and mild cardiac events (including chest pain, palpitations, tachycardia, and vasodilatation).
- Relative to placebo, the risk of PE for tamoxifen was elevated in one trial; the risk of thromboembolic events did not differ in this trial.
- In the three placebo-controlled trials of estrogen that reported cerebrovascular accident (CVA), estrogen participants had higher odds than did participants who took a placebo. In the two trials that compared an estrogen-progestin combination with placebo, the combination participants had greater odds of stroke than did placebo patients. When four estrogen studies reporting thromboemoblic events were pooled, estrogen participants had greater odds of reporting them than did placebo participants. Similar results were found when three studies comparing an estrogen-progestin combination with placebo were pooled.
- Esophageal ulcerations were reported in trials of all the bisphosphonates except zoledronic acid. The only significant difference from placebo was found in one trial where etidronate participants had higher odds of esophageal ulcers.
- Perforations, ulcerations, and bleeds (PUBs) were reported in trials of all the bisphosphonates except zoledronic acid. Etidronate participants had higher odds of PUBs than did placebo participants in three pooled studies. In two pooled trials of oral daily ibandronate, treated participants had lower odds of PUBs than did placebo participants. Differences between other bisphosphonates and placebo were not statistically significant in pooled analyses.
- We categorized conditions such as acid reflux, esophageal irritation, nausea, vomiting, and heartburn as “mild upper GI events.” Pooled analyses of 18 trials of etidronate showed greater odds for treated participants than for placebo participants. Seven pooled trials of pamidronate also showed greater odds for the drug than for placebo. Our pooled analyses found no difference between alendronate, ibandronate, risedronate, or zoledronic acid and placebo regarding mild upper GI events. In contrast, alendronate participants had higher odds of mild upper GI events than did etidronate participants in three pooled head-to-head trials. Alendronate participants also had higher odds of mild upper GI events in four head-to-head trials vs. calcitonin and four head-to-head trials vs. estrogen. Etidronate participants had higher odds of mild upper GI events in three head-to-head trials vs. estrogen.
- In five pooled trials of estrogen vs. placebo, estrogen participants had lower odds of breast cancer. Conversely, in three pooled studies of estrogen-progestin combination vs. placebo, treatment participants had higher odds of breast cancer. One estrogen-progestin study showed that treated participants had lower odds of colon cancer than did placebo participants.
- In three pooled studies of tamoxifen vs. placebo, tamoxifen participants had lower odds of breast cancer. Differences between raloxifene and placebo were not significant.
- In a pooled analysis of seven trials, estrogen participants had more gynecological problems (such as uterine bleeding) than placebo participants. The same was true for users of estrogen progestin combination in three pooled trials.
- In three pooled trials, tamoxifen participants had greater odds of gynecological probems than did placebo patients.
- Osteosarcoma was reported in only one study, a head-to-head trial of raloxifene vs. tamoxifen; differences between groups were not significant.
- There are no data from osteoporosis trials that describe an association between bisphosphonates or any other agents and the development of osteonecrosis. In case reports and case series articles, we found 41 cases of osteonecrosis of the jaw in cancer patients taking intravenous bisphosphonates. Cases involved pamidronate, zoledronic acid, and alendronate.

### Detailed Analyses

Our first analyses include the controlled trials and large cohort studies (N ≥ 1,000) found through our primary electronic searches. We focus on the adverse events that were identified as most important by our Technical Expert Panel (TEP): cardiovascular, malignancy, upper gastrointestinal, and osteonecrosis. The TEP selected specific sub-categories to focus upon, as listed below. We were specifically asked by AHRQ to include results from the Women's Health Initiative (WHI) and Heart and Estrogen-Progestin Replacement Study (HERS) trials for cardiovascular and cancer risks, although these studies did not always focus on bone-density patients.

A table that displays all the adverse events from the entire analysis is included as Appendix E. That table includes information on cancer, cardiac, dermatologic, gastrointestinal, gynecologic, immunologic, metabolic, musculoskeletal, neurological, psychiatric, and respiratory events.

To further evaluate the prevalence of selected adverse events, we were asked to perform broader post-hoc literature searches for each drug and each of the TEP's “most important” adverse events, regardless of whether the drugs were being used for bone-density treatment. Reports were selected for inclusion hierarchically by the highest level study design in the following order: meta-analysis, systematic review, observational cohort, case-control study, case series, case reports. Hence, if large cohort studies existed, there was no need to examine individual case reports. The results from these post-hoc analyses will be discussed separately, after the initial analyses.

#### Bisphosphonates

##### Cardiovascular

Acute coronary syndrome, including myocardial infarction. Acute coronary syndrome includes myocardial infarctions, coronary events, acute coronary syndromes, unstable angina, ischemic cardiac events, cardiac events requiring acute angioplasty, and cardiac events requiring coronary artery bypass graft surgery.

As shown in Table 61, there were no significant differences between any of the bisphosphonates and placebo regarding acute coronary syndrome. ^67,^ ^91,^ ^104,^ ^112,^ ^139,^ ^283,^ ^318^ – ^322^ However, two reports show an increased incidence of atrial fibrillation with bisphosphonates. In the HORIZON trial ^139^ the risk of serious atrial fibrillation was significantly increased for once-yearly zolendronic acid relative to placebo (50 versus 20 patients, p<0.001). In a letter to the editor ^323^ the authors of the FIT trial, which was included in this report reanalyzed data from that trial and reported a trend toward increased risk of atrial fibrillation with alendronate (OR = 1.26, 95% CI 0.96, 1.66); data on the atrial fibrillation were not included in the original publication.

Table 61 Bisphosphonates-adverse events vs. placebo

| Alendronate | | Etidronate | | Ibandronate | | Pamidronate | | Risedronate | | Zoledronic acid
Event Group | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 4 | 3.59 (0.35, 180) | 2 | Inf+ (0.21, Inf+) | 1 | Inf+ (0.01, Inf+) | 1 | 0(0, 37.7) | 2 | 0.38 (0.01, 7.62) | 1 | 0.98 (0.71, 1.37)
Cardiac Death | 2 | Inf+(0.13, Inf+) | 1 | Inf+ (0.03, Inf+) | 0 | NR | 1 | 0(0, 37.7) | 1 | Inf+ (0.02, Inf+) | 1 | 1.18 (0.71, 1.94)
Atrial Fibrillation | 1 | 1.26 (0.96, 1.66) | 0 | NR | 0 | NR | 0 | NR | 1 | Inf+ (0.02, Inf+) | 1 | 1.56 (1.19, 2.06)
Cerebrovascular Events (serious) | 0 | NR | 0 | NR | 2 | 0.32 (0, 27.3) | 1 | Inf+(0.09, Inf+) | 0 | NR | 1 | 0.98 (0.72, 1.34)
Pulmonary Embolism | 0 | NR | 0 | NR | 0 | NR | 0 | NR | 1 | Inf+(0.01, Inf+) | 0 | NR
Thromboembolic Events | 2 | Inf+ (0.03, Inf+) | 0 | NR | 0 | NR | 0 | NR | 0 | NR | 0 | NR
Cancer
Cancer | 2 | Inf+ (0.03, Inf+) | 3 | 3.12 (0.25, 165) | 3 | Inf+ (0.12, Inf+) | 2 | Inf+(0.4, Inf+) | 1 | 0(0, 34.5) | 0 | NR
Breast Cancer | 0 | NR | 1 | Inf+ (0.03, Inf+) | 1 | Inf+ (0.01, Inf+) | 0 | NR | 0 | NR | 0 | NR
Colon Cancer | 0 | NR | 0 | NR | 0 | NR | 1 | Inf+(0.03, Inf+) | 0 | NR | 0 | NR
Lung Cancer | 0 | NR | 1 | 0(0, 41) | 0 | NR | 1 | Inf+(0.01, Inf+) | 0 | NR | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR | 0 | NR | 0 | NR | 0 | NR | 0 | NR
GI
GI (mild) | 54 | 1.05 (0.99, 1.13) | 18 | 1.33 (1.21, 1.46)* | 10 | 1.02(0.92, 1.13) | 7 | 3.14 (1.93, 5.21)* | 22 | 1.03 (0.95, 1.13) | 3 | 1.34 (0.6, 3.21)
Upper GI (excluding esophagus) | 39 | 1(0.92, 1.07) | 15 | 1.53 (1.25, 1.88)* | 5 | 1.04(0.89, 1.22) | 4 | 4.73 (2.53, 9.35)* | 20 | 1.07 (0.96, 1.19) | 2 | 1.82 (0.53, 9.73)
Reflux and Esophageal | 27 | 1.11 (0.99, 1.23) | 0 | NR | 2 | 1.35(0.68, 2.88) | 3 | 1.49 (0.33, 9.24) | 13 | 0.90 (0.69, 1.19) | 0 | NR
GI (serious) | 20 | 1.01 (0.83, 1.24) | 7 | 1.32 (1.12, 1.55)* | 3 | 0.77(0.55, 1.08) | 4 | 2.7(0.66, 15.9) | 12 | 0.93 (0.72, 1.19) | 0 | NR
Esophageal (serious) | 8 | 1.42 (0.89, 2.29) | 1 | 1.33 (1.05, 1.68)* | 1 | 1.25(0.2, 13.1) | 1 | Inf+(0.46, Inf+) | 6 | 0.69 (0.37, 1.32) | 0 | NR
Upper GI Perforations, Ulcers, or Bleeds (not esophageal) | 12 | 0.88 (0.66, 1.18) | 3 | 1.32 (1.04, 1.67)* | 2 | 0.33 (0.14, 0.74)* | 3 | 1.67 (0.31, 11.2) | 7 | 0.64 (0.27, 1.53) | 0 | NR

* =statistically significant

Cardiac death. We found no trials of ibandronate or zoledronic acid that reported cardiac death. In trials of alendronate, ^318,^ ^319^ etidronate, ^321^ pamidronate, ^112^ risedronate, ^283^ and zoledronic acid ^139^ that reported cardiac death, there were no differences between drugs and placebo.

Cerebrovascular events (CVA). We found no trials of alendronate, etidronate, or risedronate that reported CVAs. In trials of ibandronate, ^104,^ ^106^ pamidronate, ^324^ and zoledronic acid ^139^ that reported CVA, there were no significant differences between the drugs and placebo.

Pulmonary embolism (PE). We found no trials of alendronate, etidronate, ibandronate, or zoledronic acid that reported PE. In one trial of risedronate, ^137^ difference between drug and placebo was not significant.

Venous thromboembolic events. We found no trials of etidronate, ibandronate, pamidronate, risedronate, or zoledronic acid that reported thromboembolic events. In two pooled trials of alendronate, ^67,^ ^325^ there were no significant differences between drug and placebo.

##### Malignancy

Breast Cancer. We found one placebo-controlled study each of etidronate ^326^ and ibandronate ^104^ that reported breast cancer incidence. The study found no significant differences between these drugs and placebo. Breast cancer was not reported in trials of the other bisphosphonates.

Colon Cancer. One trial of pamidronate ^327^ reported colon cancer incidence; there was no difference between the drug and placebo groups. No trials of other bisphosphonates reported colon cancer.

Lung Cancer. We found one placebo-controlled study each of etidronate ^326^ and pamidronate ^324^ that reported lung cancer. There were no significant differences between these drugs and placebo. Lung cancer was not reported in trials of the other bisphosphonates.

Osteosarcoma. Osteosarcoma was not reported in any bisphosphonate trials.

##### Upper gastro-intestinal

Esophageal ulcerations. Esophageal ulcerations were reported in trials of all the bisphosphonates except zoledronic acid. The only significant difference was found in one study, ^328^ where etidronate participants had higher odds of esophageal ulcers than did the placebo group (OR 1.33, 95% CI 1.05, 1.68).

Perforations, ulcerations, and bleeds (PUBs). These were reported in trials of all the bisphosphonates except zoledronic acid. Etidronate participants had higher odds of PUBs than did placebo participants in three ^89,^ ^328,^ ^329^ pooled studies (OR 1.32, 95% CI 1.04, 1.67). In two pooled trials of oral daily ibandronate, ^105,^ ^330^ participants had lower odds than did placebo participants (OR 0.33, 95% CI 0.14, 0.74).

Other upper GI, mild. We categorized conditions such as acid reflux, esophageal irritation, nausea, vomiting, and heartburn as “upper GI events, mild.” Pooled analyses of 18 studies of etidronate ^90^ – ^95,^ ^98,^ ^101,^ ^274,^ ^275,^ ^280,^ ^281,^ ^326,^ ^328,^ ^331^ – ^334^ showed greater odds of mild upper GI events than did placebo (OR 1.33, 95% CI 1.21, 1.46). Seven pooled trials of pamidronate ^110,^ ^112,^ ^324,^ ^327,^ ^335^ – ^337^ also showed greater odds than did placebo (OR 3.14, 95% CI 1.93, 5.21). There were no differences between alendronate, ibandronate, risedronate, or zoledronic acid and placebo regarding mild upper GI events.

There were also significant results in head-to-head studies (not shown, see Appendix E). Alendronate participants had higher odds of mild upper GI events than did etidronate participants in three pooled head-to-head studies. ^252,^ ^338,^ ^339^ Alendronate participants also had higher odds of mild upper GI events in four head-to-head trials vs. calcitonin ^73,^ ^320,^ ^340,^ ^341^ and four vs. estrogen. ^66,^ ^67,^ ^342,^ ^343^ Etidronate participants had higher odds of mild upper GI events in seven head-to-head trials vs. calcium ^92,^ ^96,^ ^344^ – ^348^ and three head-to-head trials vs. estrogen. ^91,^ ^93,^ ^345^

##### Other statistically significant results (Not shown, see Appendix E)

Musculoskeletal. This category includes muscular and joint pain, arthritis, and muscle cramps. Risedronate participants had lower odds of musculoskeletal events than did placebo participants in nine pooled trials ^120,^ ^123,^ ^134,^ ^136,^ ^137,^ ^273,^ ^349,^ ^349,^ ^350,^ ^350^ – ^352^ (OR 0.40, 95% CI 0.29, 0.54). In three pooled trials, ^138,^ ^139,^ ^353^ zoledronic acid participants had higher odds of these events than did placebo participants (OR 4.52, 95% CI 3.78, 5.43). In two head-to-head trials, ^259,^ ^354^ alendronate participants had greater odds of these events than did participants taking PTH (OR 3.84, 95% CI 2.22, 6.80).

Metabolic. In two trials, alendronate patients had increased odds of hypocalcemia relative to placebo patients (nine of 301 treatment patients versus none of 207 placebo patients). Increased odds of hypercalcemia were also reported in a trial of zoledronic acid. ^139^

#### SERMS

##### Cardiovascular

Acute coronary syndrome, including myocardial infarction. As displayed in Table 62, in three trials of raloxifene ^166,^ ^355,^ ^356^ and one trial of tamoxifen, ^204^ there were no significant differences between either drug and placebo.

Table 62 SERM-adverse events vs. placebo

| Raloxifene | | Tamoxifen
Event Group | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 3 | 1.23(0.92, 1.66) | 1 | 1.19(0.9, 1.58)
Cardiac Death | 2 | 1.25(0.6, 2.78) | 1 | 1.26(0.79, 2.03)
Cerebrovascular Events (serious) | 3 | 1.22(0.89, 1.68) | 1 | 1.16(0.79, 1.72)
Pulmonary Embolism | 2 | 6.26(1.55, 54.8)* | 1 | 3.52(1.37, 10.7)*
Thromboembolic Events | 7 | 2.08(1.47, 3.02)* | 1 | 1.6(0.91, 2.87)
Cancer
Cancer | 5 | 0.9(0.42, 2.04) | 5 | 0.6(0.53, 0.69)*
Breast Cancer | 2 | 0.71(0.1, 7.97) | 3 | 0.49(0.42, 0.57)*
Colon Cancer | 0 | NR | 1 | 1.24(0.56, 2.8)
Lung Cancer | 2 | 0.39(0.01, 7.87) | 1 | 1(0.57, 1.76)
Osteosarcoma | 0 | NR | 0 | NR
GI
GI (mild) | 8 | 0.97(0.78, 1.21) | 1 | 1(0.01, 82)
Upper GI (excluding esophagus) | 3 | 1.1(0.68, 1.81) | 0 | NR
Reflux and Esophageal | 0 | NR | 0 | NR
GI (serious) | 1 | 0.49(0.01, 39.1) | 0 | NR
Esophageal (serious) | 0 | NR | 0 | NR
Upper GI Perforations, Ulcers, or Bleeds (not esophageal) | 0 | NR | 0 | NR

* =statistically significant

Cardiac death. Two trials of raloxifene ^355,^ ^356^ and one of tamoxifen ^204^ reported cardiac deaths. There were no significant differences between either drug and placebo.

CVA. Three trials of raloxifene ^356^ – ^358^ and one of tamoxifen ^204^ reported CVA. There were no significant differences between either drug and placebo.

PE. Two large studies ^355,^ ^359^ showed higher odds for PE among raloxifene participants than among placebo participants (OR 6.26, 95% CI 1.55, 54.80). Tamoxifen ^204^ also showed higher odds of PE than did placebo in one study (OR 3.52, 95% CI 1.37, 10.70).

Venous thromboembolic events. Raloxifene participants had greater odds of thromboembolic events than did placebo participants in seven pooled studies ^201,^ ^325,^ ^355,^ ^358,^ ^360^ – ^362^ (OR 2.08, 95% CI 1.47, 3.02). In one study of tamoxifen, differences with placebo were not significant. ^204^

##### Malignancy

Breast Cancer. In three pooled studies of tamoxifen vs. placebo, ^204,^ ^363,^ ^364^ tamoxifen participants had lower odds of breast cancer (OR 0.60, 95% CI 0.53, 0.69). Differences between raloxifene and placebo were not significant in two pooled trials. ^355,^ ^360^

Colon Cancer. One placebo-controlled study of tamoxifen reported colon cancer. ^204^ Differences between groups were not significant. No studies of raloxifene reported colon cancer. A study comparing raloxifene with tamoxifen also reported colon cancer; differences between the drugs were not significant (not shown).

Lung Cancer. We found two placebo-controlled trials of raloxifene, ^355,^ ^359^ and one of tamoxifen ^204^ that reported lung cancer, as did one study comparing raloxifene with tamoxifen. There were no significant differences in any studies.

Osteosarcoma. We found one head-to-head study of raloxifene vs. tamoxifen that reported bone cancer. Differences between groups were not significant (see Appendix E).

##### Upper gastro-intestinal

Esophageal ulcerations and ii. PUBs. These events were not reported in trials of raloxifene and tamoxifen.

Other upper GI, mild. In eight pooled trials of raloxifene ^166,^ ^203,^ ^325,^ ^355,^ ^357,^ ^360,^ ^362,^ ^365^ and one trial of tamoxifen, ^366^ differences between drug and placebo were not significant.

##### Other statistically significant results (Not shown, see Appendix E)

Cardiac, mild. This category includes chest pain, palpitations, tachycardia, and vasodilatation. In a pooled analysis of six trials, raloxifene participants had higher odds of mild cardiac events than did placebo participants (OR 1.53, 95% CI 1.01, 2.25).

Musculoskeletal. This category includes muscular and joint pain, arthritis, and muscle cramps. In three head-to-head trials, ^166,^ ^367,^ ^368^ raloxifene participants had greater odds of these events than did participants taking estrogen (OR 2.44, 95% CI 1.27, 5.02).

Gynecologic. This category includes uterine problems such as endometrial bleeding. In three pooled trials, ^204,^ ^366,^ ^369^ tamoxifen participants had greater odds of gynecological problems than did placebo participants (OR 2.33, 95% CI 2.17, 2.50).

#### Estrogen or estrogen plus progestin

##### Cardiovascular

Acute coronary syndrome, including myocardial infarction. As displayed in Table 63, in the five trials of estrogen ^67,^ ^91,^ ^165,^ ^166,^ ^370^ and two trials of estrogen plus progestin ^164,^ ^371^ that reported these events, there were no significant differences between treatment and placebo groups.

Table 63 Estrogen-adverse events vs. placebo

| Estrogen | | Estrogen with progesterone
Event Group | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 5 | 0.94(0.76, 1.18) | 2 | 0.96(0.86, 1.09)
Cardiac Death | 2 | 0.92(0.71, 1.2) | 2 | 1.18(0.91, 1.54)
Cerebrovascular Events (serious) | 3 | 1.34(1.07, 1.68)* | 2 | 1.28(1.05, 1.57)*
Pulmonary Embolism | 1 | 0.98(0.13, 7.37) | 1 | 2.77(0.82, 12)
Thromboembolic Events | 4 | 1.36(1.01, 1.86)* | 3 | 2.27(1.72, 3.02)*
Cancer
Cancer | 5 | 0.86(0.75, 0.99)* | 5 | 1.07(0.94, 1.22)
Breast Cancer | 5 | 0.79(0.66, 0.93)* | 3 | 1.28(1.03, 1.6)*
Colon Cancer | 1 | 1.08(0.74, 1.57) | 1 | 0.64(0.43, 0.95)*
Lung Cancer | 0 | NR | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR
GI
GI (mild) | 6 | 1(0.65, 1.52) | 2 | 1.38(0.97, 1.97)
Upper GI (excluding esophagus) | 2 | 1.05(0.25, 6.29) | 2 | 0.71(0.38, 1.26)
Reflux and Esophageal | 2 | 0.68(0.37, 1.24) | 1 | 0(0, 0.81)*
GI (serious) | 0 | NR | 0 | NR
Esophageal (serious) | 0 | NR | 0 | NR
Upper GI Perforations, Ulcers, or Bleeds (not esophageal) | 0 | NR | 0 | NR

* =statistically significant

Cardiac death. In the two trials of estrogen ^165,^ ^370^ and two trials of estrogen plus progestin ^164,^ ^371^ that reported cardiac deaths, there were no significant differences between treatment and placebo groups.

CVA. We pooled three trials comparing estrogen with placebo; ^165,^ ^185,^ ^370^ the estrogen group had an odds ratio of 1.34 (95% CI, 1.07, 1.68) for CVA. We also pooled two trials comparing an estrogen-progestin combination with placebo; ^164,^ ^371^ the combination participants had greater odds of stroke than did placebo participants (OR 1.28, 95% CI, 1.05, 1.57).

PE. In one trial of estrogen ^370^ and one trial of estrogen plus progestin, ^371^ there were no significant differences between treatment and placebo groups.

Venous thromboembolic events. Estrogen participants had greater odds of thromboembolic events than did placebo participants in four pooled studies ^67,^ ^165,^ ^185,^ ^370^ (OR 1.36, 95% CI, 1.01, 1.86). Similar results were found when three studies comparing an estrogen-progestin combination with placebo ^164,^ ^191,^ ^371^ were pooled (OR 2.27, 95% CI, 1.72, 3.02).

##### Malignancy

Breast Cancer. In five pooled trials of estrogen vs. placebo, ^165,^ ^185,^ ^370,^ ^372,^ ^373^ estrogen participants had lower odds of breast cancer (OR 0.79, 95% CI, 0.66, 0.93). Conversely, in three pooled studies of estrogen-progestin combination vs. placebo, ^164,^ ^184,^ ^371^ treatment participants had higher odds of breast cancer (OR 1.28, 95% CI, 1.03, 1.60).

Colon Cancer. We found one placebo-controlled trial each of estrogen ^165^ and estrogen-progestin combined ^164^ that reported on colon cancer. Only the estrogen-progestin study showed a significant difference: treated participants had lower odds of colon cancer than did placebo participants (OR 0.64, 95% CI, 0.43, 0.95).

Lung Cancer. No trials of estrogen or progestin reported lung cancer.

Osteosarcoma. No trials of estrogen or progestin reported osteosarcoma.

Upper gastro-intestinal

Esophageal ulcerations and ii. PUBs. These events were not reported in trials of estrogen or estrogen-progestin combination.

Other upper GI, mild. Combination estrogen-progestin participants had lower odds than did placebo participants of mild reflux and esophageal events in two studies ^256,^ ^371^ (OR 0.0, 95% CI, 0.0, 0.81). Other comparisons were not significant. Alendronate and etidronate participants had higher odds of mild upper GI events in head-to-head trials vs. estrogen (see Appendix E).

##### Other statistically significant results (Not shown, see Appendix E)

Genitourinary. This category includes prostate problems, erectile dysfunction, dysuria, and urinary incontinence. Two trials each showed greater odds for estrogen and estrogen-progestin combination participants than for placebo participants. ^82,^ ^166^

Gynecologic. This category includes uterine problems such as endometrial bleeding. In a pooled analysis of seven trials, ^67,^ ^168,^ ^185,^ ^367,^ ^370,^ ^374,^ ^375^ estrogen participants had greater odds of gynecological problems than did placebo participants (OR 7.18, 95% CI, 5.31, 9.82). Similarly, estrogen-progestin combination participants had greater odds of these problems than did placebo participants in three pooled trials (OR 58.10, 95% CI, 9.03, 245.20). ^184,^ ^191,^ ^375^

Breast abnormality, other than cancer. This category includes pain, tenderness, and fibrocysts. In a pooled analysis of seven trials, ^67,^ ^93,^ ^166,^ ^168,^ ^367,^ ^372,^ ^376^ estrogen participants had greater odds of breast abnormalities than did placebo participants (OR 3.79, 95% CI, 2.64, 5.50). Similarly, estrogen-progestin combination participants had greater odds of these problems than did placebo participants in three pooled trials (OR 7.42, 95% CI, 3.79, 15.20). ^184,^ ^191,^ ^256^ In four head-to-head trials, ^166,^ ^367,^ ^368,^ ^376^ raloxifene participants had far lower odds of breast abnormalities than did estrogen participants (OR 0.09, 95% CI, 0.07, 0.13). Two head-to-head trials each of alendronate ^67,^ ^342^ and etidronate ^93,^ ^345^ vs. estrogen and one trial of risedronate ^256^ and zoledronic acid ^256^ vs. estrogen-progestin all showed that participants taking the bisphosphonates had lower odds of breast abnormalities than did participants taking estrogen.

#### Vitamin D and calcium

Cardiovascular. Serious cardiovascular adverse events were not reported in trials of vitamin D or calcium (Table 64).

Table 64 Calcium & vitamin D-adverse events vs. placebo

| Calcium | | Vitamin D
Event Group | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 0 | NR | 0 | NR
Cardiac Death | 0 | NR | 0 | NR
Cerebrovascular Events (serious) | 0 | NR | 0 | NR
Pulmonary Embolism | 0 | NR | 0 | NR
Thromboembolic Events | 0 | NR | 0 | NR
Cancer
Cancer | 0 | NR | 0 | NR
Breast Cancer | 0 | NR | 0 | NR
Colon Cancer | 0 | NR | 0 | NR
Lung Cancer | 0 | NR | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR
GI
GI (mild) | 2 | 0.79(0.33, 1.87) | 3 | 0.27(0.04, 1.11)
Upper GI (excluding esophagus) | 2 | 0.79(0.33, 1.87) | 2 | 0.27(0.04, 1.11)
Reflux and Esophageal | 0 | NR | 0 | NR
GI (serious) | 0 | NR | 0 | NR
Esophageal (serious) | 0 | NR | 0 | NR
Upper GI Perforations, Ulcers or Bleeds (not esophageal) | 0 | NR | 0 | NR

Malignancy. Cancers were not reported in any trials of vitamin D or calcium.

##### Upper gastro-intestinal

Esophageal ulcerations and ii. PUBs. These events were not reported in trials of vitamin D or calcium.

Other upper GI, mild. In two trials of calcium ^92,^ ^269^ and two trials of vitamin D, ^93,^ ^377^ there were no significant differences between treatment and placebo groups regarding mild upper GI adverse events.

#### Calcitonin, testosterone, and PTH

##### Cardiovascular

Acute coronary syndrome, including myocardial infarction. As displayed in Table 65, there were no trials of testosterone or PTH that reported these events. Three trials of calcitonin ^148,^ ^320,^ ^378^ reported acute coronary syndrome; the differences between calcitonin and placebo were not significant.

Table 65 Calcitonin, PTH, and testosterone-adverse events vs. placebo

| Calcitonin | | Testosterone | | PTH
Event Group | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 3 | 0.98 (0.07, 13.7) | 0 | NR | 0 | NR
Cardiac Death | 1 | 0 (0, 36.6) | 0 | NR | 0 | NR
Cerebrovascular Events (serious) | 1 | 1.03 (0.07, 14.9) | 1 | Inf+ (0.03, Inf+) | 0 | NR
Pulmonary Embolism | 0 | NR | 0 | NR | 0 | NR
Thromboembolic Events | 0 | NR | 0 | NR | 0 | NR
Cancer
Cancer | 1 | Inf+ (0.02, Inf+) | 2 | 3.1 (0.24, 168) | 3 | 0.49 (0.27, 0.9)*
Breast Cancer | 0 | NR | 0 | NR | 0 | NR
Colon Cancer | 0 | NR | 0 | NR | 0 | NR
Lung Cancer | 0 | NR | 0 | NR | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR | 0 | NR
GI
GI (mild) | 15 | 0.96 (0.63, 1.48) | 0 | NR | 2 | 1.39(0.98, 2)
Upper GI (excluding esophagus) | 8 | 1.07 (0.55, 2.1) | 0 | NR | 2 | 1.39(0.98, 2)
Reflux and Esophageal | 1 | 0(0, 0.69)* | 0 | NR | 0 | NR
GI (serious) | 0 | NR | 0 | NR | 0 | NR
Esophageal (serious) | 0 | NR | 0 | NR | 0 | NR
Upper GI Perforations, Ulcers or Bleeds (not esophageal) | 0 | NR | 0 | NR | 0 | NR

* =statistically significant

Cardiac death. There were no trials of testosterone or PTH that reported cardiac death. One trial of calcitonin reported cardiac death; ^148^ the difference between calcitonin and placebo was not significant.

CVA. One trial of calcitonin ^378^ and one trial of testosterone ^379^ reported CVA. Differences were not significant from placebo. No trials of PTH reported CVA.

PE and v. venous thromboembolic events. We found no trials of calcitonin, testosterone, or PTH that reported PE or thromboembolic events.

Malignancy. Cancers were reported in one trial of calcitonin, ^380^ two trials of testosterone, ^379,^ ^381^ and three trials of PTH. ^196,^ ^198,^ ^382^ PTH participants had lower odds of cancer than did placebo participants (OR 0.49, 95% CI, 0.27, 0.90). Incidences for specific types of cancers such as breast cancer, colon cancer, lung cancer, or osteosarcoma were not reported in these trials.

##### Upper gastro-intestinal

Esophageal ulcerations and ii. PUBs. These events were not reported in trials of calcitonin, testosterone, and PTH.

Other upper GI, mild. In 15 trials of calcitonin ^73,^ ^93,^ ^143,^ ^148,^ ^152,^ ^320,^ ^340,^ ^341,^ ^380,^ ^383^ – ^388^ and two trials of PTH, ^198,^ ^382^ there were no significant differences between treatment and placebo groups regarding mild upper GI adverse events.

##### Other statistically significant results (Not shown, see Appendix E)

Cardiac, mild. This category includes chest pain, palpitations, tachycardia, and vasodilatation. In two pooled head-to-head trials, ^389,^ ^390^ calcitonin participants had greater odds of mild cardiac events than did PTH participants (no events in 81 PTH participants, five events in 86 calcitonin participants).

Musculoskeletal. In two head-to-head trials, ^259,^ ^354^ alendronate participants had greater odds of these events than did participants taking PTH (OR 3.84, 95% CI, 2.22, 6.80).

Dermatological. This category includes itching, rash, and injection site reactions. In eight pooled trials, ^148,^ ^149,^ ^152,^ ^386,^ ^388,^ ^391^ – ^393^ calcitonin participants had greater odds of these symptoms than did placebo participants (OR 6.13, 95% CI, 2.81, 14.90). In two pooled trials, ^394,^ ^395^ testosterone participants had greater odds of dermatological symptoms than did placebo participants (OR 8.64, 95% CI, 2.94, 29.70).

Ear, nose, and throat. In nine pooled trials, ^152,^ ^340,^ ^341,^ ^378,^ ^380,^ ^384,^ ^386,^ ^387,^ ^392^ calcitonin participants had greater odds of these events than did placebo participants (OR 2.31, 95% CI, 1.13, 4.99).

#### Additional cohort, case-control, case series, and case report studies

To further evaluate the prevalence of selected adverse events, we performed broader literature searches for each low bone density treatment and cancers, cardiovascular events, gastrointestinal problems, and osteonecrosis. The “treatments” were not necessarily being used for low bone density. We found many additional cohort studies involving cancer, and several case series/case reports on osteonecrosis. We found no additional studies of cardiovascular events or gastrointestinal problems.

##### Cancer

We found eight large cohort or case-control studies examining the effect of calcium and/or vitamin D intake on the incidence of cancer. Results are displayed below in Table 66. In one study of breast cancer among women, increased dietary calcium was associated with lower risk (RR 0.80, CI 0.67–0.95). In contrast, one study of prostate cancer showed that increased dietary calcium was associated with higher risk (RR 2.2, CI 1.2–3.9). Vitamin D intake was not associated with either breast or prostate cancer.

Table 66 Calcium/vitamin D observational studies

Study | Medications | Findings
Cancer Prevention Study II ^396^ | Calcium, Vitamin D | Women with the highest intake of dietary calcium were at lower risk of breast cancer than were those with the lowest intake (RR 0.80, CI 0.67–0.95). Neither use of supplemental calcium or vitamin D intake was associated with risk.
NHANES Follow-up ^397^ | Calcium, Vitamin D | Men with the highest intake of dairy food were at higher risk of prostate cancer than were those with the lowest intake (RR 2.2, CI 1.2–3.9). Dietary calcium was also strongly associated with increased risk (RR 2.2, CI 1.4–3.5). After adjustment for calcium intake, vitamin D was not associated with risk.
Veterans Affairs cohort ^398^ | Calcium, Vitamin D | In multivariate analyses, inverse associations were found for vitamin D intake (OR 0.94, CI 0.90–0.99) and colorectal cancer. Calcium intake was not significantly associated with colorectal cancer.
Nurses Health Study & Health Professionals Follow-up Study ^399^ | Calcium | In men and women, an inverse association was found between higher calcium intake and distal colon cancer (RR 0.65, CI 0.43–0.98).
Swedish Cancer Foundation ^400^ | Calcium, Vitamin D | Consumption of milk and total milk products was inversely related to colon cancer, but not at traditionally accepted significance levels (p=.06). No association was found for rectal cancer. Vitamin D intake and total dietary calcium were not related to colorectal cancer risk.
Iowa Women's Study ^401^ | Calcium, Vitamin D | Total calcium intake was inversely associated with colon cancer among women with a negative family history (RR 0.50) but unrelated to incidence for women with a positive family history.
Netherlands Cohort Study ^402^ | Calcium | For men and women, totally dietary calcium intake and calcium from fermented dairy products were not significantly associated with colorectal cancer risk. Calcium from unfermented dairy projects was inversely associated with rectal cancer risk (RR 0.55, CI 0.30–1.04).
Hawai'i Japanese Men ^403^ | Calcium | Total calcium intake was not related to risk of colon cancer, and separation of calcium into dairy and nondairy sources did not alter the result. However, there was a significant monotonic increase in sigmoid colon cancer risk with decreasing total calcium intake.

In six studies, greater calcium intake was found to be either inversely associated with colorectal cancers or not statistically related. Vitamin D was not associated with these cancers, except in one study that showed an inverse relationship with increasing intake.

We found four large cohort or case-control studies regarding estrogen and estrogen-progestin combinations and colorectal cancers among women. Results are summarized in Table 67. In three studies, use of estrogen as hormone replacement therapy was inversely associated with these cancers. One study showed no association.

Table 67 Estrogen observational studies on colorectal cancer

Study | Medications | Findings
Leisure World Cohort, U.S. ^404^ | Estrogen - hormone replacement therapy | Elderly women who used hormone replacement therapy had age adjusted incidence rate of 2.67 per 1,000 persons compared with 3.30 per 1,000 persons for non-users.
Italy ^405^ | Estrogen - hormone replacement therapy | Ever-use of hormone replacement therapy was inversely associated with colon cancer (OR 0.64, CI 0.46–0.88) and rectal cancer (OR 0.46, CI 0.29–0.72). Increased duration of use was associated with decreasing risk for both cancers (p for trend < .01)
Cancer II Prevention Study, U.S. ^406^ | Estrogen - hormone replacement therapy | Ever-use of hormone replacement therapy was inversely associated with fatal colon cancer (RR 0.71, CI 0.61–0.83). Increased duration of use was associated with decreasing risk for colon cancer (p for trend < .001)
Saskatchewan Health Plan, Canada ^407^ | Estrogen, progestin, or combination | No association between colon cancer risk and the medications.

We found other observation studies of bisphosphonates, SERMs, calcitonin, testosterone, or PTH and cancer incidence or prevalence.

##### Osteonecrosis

We found seven articles reporting a total of 41 separate cases of osteonecrosis of the jaw in patients taking bisphosphonates. Cases involved pamidronate, zoledronic acid, and alendronate. The vast majority of cases were found in cancer patients taking the medications intravenously. All patients were advised to cease taking the medications. Surgical treatments varied in type and result.

We found no reports of other low bone density treatments and osteonecrosis.