# 2 Methods

## Topic Development and Technical Expert Panel

The topic for this report was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) located at Oregon Health and Science University (OHSU) drafted the initial key questions and, after approval from AHRQ, posted them to a public web site. The public was invited to comment on these questions. After reviewing the public commentary, the SRC drafted final key questions and submitted them to AHRQ for approval.

The key questions subsequently went through several revisions. An original question on whether change in bone density is an adequate intermediate endpoint for treatment effectiveness was removed in October, 2005, based on discussion with AHRQ and our Technical Expert Panel (TEP). In addition, an original question asking for review of practical and validated tools that can be used by patients or clinicians to predict the risk of fracture and the benefits of treatment was declared beyond the scope of this review in December, 2005. In response to comments on the first draft of this report, a key question about the effect of treatment adherence and persistence of medications on fracture was added.

Our TEP met by conference call on October 12, 2005, January 11, 2006, and September 12, 2006. Additionally, we conferred with the FDA by teleconference on September 26, 2006. At the October meeting, the TEP suggested we focus on the bisphosphonates, SERMs, Calcitonin, and PTH. They noted that calcium, vitamin D, hormones, and exercise had already been reviewed extensively; thus, they suggested that we summarize existing reviews on these interventions and incorporate study-level data for these interventions only in comparison to agents of primary interest. At the January 2006 meeting, due to the amount of literature found and time constraints, we suggested limiting the efficacy analyses to trials with fracture outcomes. The TEP found this suggestion acceptable but advised us not to pool data across different fracture types. Thus, we do not analyze intermediate outcomes such as bone mineral density or markers of bone turnover.

The September 2006 TEP meeting focused on adverse events (AE) and risk groups. The September 2006 call with the FDA focused on AE analysis. Based on these calls and discussions with AHRQ, the following AE were defined as particularly important for one or more of the agents being reviewed in this report: 1) cardiovascular: myocardial infarction, stroke; 2) thromboembolic events: pulmonary embolism, venous thrombo-embolic events; 3) malignancies: breast cancer, colon cancer, lung cancer, osteosarcoma; 4) upper GI events: perforations, ulcers, bleeds, esophageal ulcerations; 5) osteonecrosis; 6) inflammatory eye reactions: uveitis, scleritis; 6) acute phase reactions. It was decided to expand the search strategy for these key AE (see below).

Risk groups (high, intermediate, low, and unknown) were defined based on combinations of risk factors that would be reported in clinical trials, including BMD, fracture history, age, comorbidities, or treatment with drugs that increase the risk for fracture. The risk groups are also defined below.

## Search Strategy

This report incorporated three main searches: one to identify studies of the drugs of interest to this report, one to identify key AE associated with these drugs, and one to identify studies that described adherence to and persistence with the drugs. We also performed a targeted search to identify studies from the Women's Health Initiative and the Heart and Estrogen/Progestin Replacement Study (HERS).

Given the large volume of literature in this area and the fact that a number of systematic reviews and meta-analyses had previously been published, we used a two-pronged approach to identify articles for this report. First we identified any systematic reviews and meta-analyses that reported on the effect of agents of interest on fracture risk. When relevant systematic reviews or meta-analyses were identified for specific agents, we truncated our search for those specific agents to include dates after the last search date used in the review/meta-analysis.

For the three main searches, our basic search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE® and was adapted for use in the other databases. We searched MEDLINE® for the period from 1966 to December 2006. We also searched the American College of Physicians (ACP) Journal Club database and the Cochrane controlled trials register. Our search was not limited by publication type (e.g. reports of randomized controlled trials, systematic reviews). Nevertheless, to identify additional systematic reviews and meta-analyses not captured in our primary search strategy, we also searched MEDLINE®, the Cochrane Database of Systematic Reviews, the websites of the National Institute for Clinical Excellence, and the NHA Health Technology Assessment Programme. We also manually searched reference lists of review articles obtained as part of our search. (We refer to this process as “reference mining.”) The texts of the major search strategies are shown in Appendix A.

In our search to identify clinical studies of drugs of interest to this review, we used terms for osteoporosis, osteopenia, low bone density, and the drugs listed in the key questions. In our search for the key AE, we used terms for the AE and each of the drugs of interest for this report. In our search for adherence and persistence we used terms for adherence and persistence and the drugs of interest for this report. In all cases both generic and trade names were used. The texts of the major search strategies are shown in Appendix A. To supplement the information in systematic reviews on the effects of estrogen on fracture and on AE associated with estrogen, we were asked to review studies from the Women's Health Initiative (WHI) and Heart and Estrogen-progestin Replacement Study (HERS) trials. The WHI studies were identified from a website (http://www.nhlbi.nih.gov/whi/references.htm) that provides a comprehensive list of manuscripts published from this study. Reports from the HERS trial were identified through a MEDLINE® search.

We invited TEP members to provide additional studies. Studies suggested by stakeholders during the public review period were also reviewed. In addition, we received the following materials from the Scientific Resource Center:

- Medical and statistical reviews of all FDA-approved drugs listed in the key questions, obtained from the FDA web site;
- Scientific information packets from:

Auxilium Pharmaceuticals | - Testum® (Testosterone)
Novartis | - Miacalcin® (Calcitonin)
Merck | - Fosamax® (Alendronate)
Eli Lilly | - Evista® (Raloxifene)
| - Forteo® (Teriparatide)
Roche | - Boniva® (Ibandronate)
Proctor & Gamble | - Actonel® (Risedronate).

All citations were imported into an electronic database using ProCite.

## Study Selection

Three sets of inclusion criteria were developed: one each for the efficacy, AE, and adherence/persistence analyses. For titles obtained through the searches for studies of drugs and osteoporosis/osteopenia and low bone density, we accepted any title that suggested the manuscript might include information on fracture, BMD, markers of bone turnover, or any AE. For titles obtained from the search for AEs by drug of interest, titles were accepted if they suggested that the manuscript included information on the relationship between the AE and the drug. Likewise, for the titles identified from the search for adherence and compliance, titles were accepted if they suggested that the manuscript might include information on adherence and compliance. Titles identified for the first two searches were reviewed independently by two reviewers. All titles selected by either reviewer went on to the screening phase. Titles identified for the adherence/persistence search were reviewed by a single reviewer. Full text articles were obtained for all articles that were accepted for the screening phase.

At the screening phase, all articles identified through the searches for efficacy or AE were reviewed independently by two physicians using a structured screening form (Appendix B). Reviewers reconciled their answers from the review form and came to consensus on any disagreements. The principal investigator resolved any disagreements between reviewers. Articles identified through the search for adherence/persistence were screened by a single reviewer.

At this stage, articles could be accepted for further review for either the efficacy (fracture) or adverse events analysis. Controlled clinical trials that reported fracture outcomes for one or more of the drugs of interest were accepted for the efficacy analysis and went on to data extraction. Controlled clinical trials and large case control or cohort studies (n ≥ 1000) that reported fracture or BMD or markers of bone turnover for one or more of the drugs of interest and that reported one or more AE went on for AE analyses. Also included in AE analysis were articles that were identified through the search for specific AE, if any AE for any of the drugs of interest was reported. Articles of any study design that reported on adherence/persistence for any of the drugs of interest went on for further evaluation.

## Data Extraction

Articles that met screening criteria for the efficacy analysis were further reviewed using the “quality review form” included in Appendix B. We extracted the following data from the controlled clinical trials: setting; geographic region; population characteristics (including sex, age, ethnicity, diagnosis); eligibility and exclusion criteria; interventions (dose and duration); concurrent medications or supplements; number screened, eligible, enrolled, and lost to follow-up; method of outcome ascertainment; and type of outcome reported. We also abstracted run-in period and wash-out period where applicable. Data from each article were independently abstracted by two physicians trained in the critical assessment of evidence. They resolved disagreements by consensus; the principal investigator resolved any disagreements that remained after their discussion.

A statistician extracted the fracture outcome data. For each treatment or placebo arm within an RCT, the sample size and number of persons reporting fractures were extracted.

Articles that screened in for the adverse events analysis were each abstracted independently by two reviewers under the supervision of the statistician. Disagreements were resolved by the statistician and/or the principal investigator. Adverse events were recorded onto a spreadsheet that identified each trial group, the description of the adverse event as listed in the original article, and the number of subjects in each group. Each event was counted as if it represented a unique individual. Because a single individual might have experienced more than one event, this assumption may have overestimated the number of people having an adverse event. If a trial mentioned a particular type of adverse event in the discussion but did not report data on that adverse event, we did not include that trial in that particular event's analysis. In other words, we did not assume zero events occurred unless the trial report specifically stated that zero events were observed. By taking this approach, we may have overestimated the number of patients for whom a particular adverse event was observed.

Articles that screened in for the adherence/persistence analysis were further reviewed by a single reviewer who abstracted relevant data from each article in a qualitative fashion. Per the Scientific Resource Center, we abstracted the aims, time period covered, eligibility criteria, study designs included, interventions studied, populations, and results from systematic reviews and meta-analyses. These data are presented in the evidence tables (Appendix C).

## Quality Assessment

We used predefined criteria to assess the quality of systematic reviews and individual RCTs. As observational studies were not used for efficacy analyses, we felt that quality rating was unnecessary.

Before we assessed the quality of systematic reviews and meta-analyses, we reviewed the QUOROM statement, ^27^ which consists of a checklist of 18 items and a flow diagram. The statement's authors were able to identify scientific evidence for only eight items. As the authors did not suggest a specific scoring mechanism for the checklist, we focused on aspects of internal and external validity as suggested in the Medicare Modernization Act (MMA) Drug Review Methods Manual distributed in March, 2005. These items, which include search strategy, inclusion criteria for individual studies, and method of synthesis, among others, are presented in the evidence table for systematic reviews in Appendix C. Each systematic review or meta-analyses is discussed in detail in its corresponding section of the results.

We assessed the quality of individual RCTs using the Jadad scale, which was developed for drug trials and which we feel is well suited to the evaluation of quality in this report. The Jadad scale ranges from 0–5 based on points given for randomization, blinding, and accounting for withdrawals and dropouts. ^28^ Across a broad array of meta-analyses, an evaluation found that studies scoring 0–2 report exaggerated results compared with studies scoring 3–5. ^29^ The latter have been called “good” quality and the former called “poor” quality.

## Applicability

Effectiveness studies compare a new drug with viable alternatives rather than with placebos and produce health, quality of life, and economic outcomes data under real-world conditions. For example, an effectiveness trial of a new asthma drug would include asthma-related emergency room visits, the frequency and costs of physician visits, patients' quality of life, patient compliance with the medications, acquisition costs of the medications, and frequency and costs of short- and long-term adverse events." ^30^

Clinicians and policymakers often distinguish between the [underlined: efficacy] of an intervention (the extent to which the treatment works under ideal circumstances) and the [underlined: effectiveness] of the intervention (the extent to which the treatment works on average patients in average settings). Efficacy studies tend to be smaller, to be performed on referred patients and in specialty settings, and to exclude patients with comorbidities. Effectiveness studies are larger and more generalizable to practice. The vast majority of studies included in our report are efficacy studies. However, our analysis of adherence and persistence provides some information about effectiveness in that adherence and persistence influence effectiveness.

## Rating the Body of Evidence

We assessed the overall strength of evidence for outcomes using a method developed by the Grade Working Group, which classified the grade of evidence across outcomes according to the following criteria: ^31^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## Data Synthesis

We performed three main analyses: one to evaluate efficacy, one to evaluate adherence, and one to evaluate AE. Comparisons of interest for all analyses were single drug versus placebo for each of the drugs of interest, and single drug versus single drug comparisons for drugs within the same class and across classes. In addition we evaluated comparisons between estrogen combined with progesterone and placebo or single drugs. Studies that included either calcium or vitamin D in both study arms were classified as being comparisons between the other agents in each arm, e.g., alendronate plus calcium versus risedronate plus calcium would be classified as alendronate versus risedronate.

### Efficacy

The efficacy outcome of interest for this report is fractures. We report data about the following types of fractures (as reported in the studies reviewed)—vertebral, non-vertebral, hip, wrist, and humerus. For each of the drug comparisons, we summarized fracture data from published systematic reviews and meta-analyses in tables. Data abstracted from individual controlled clinical trials were grouped by fracture type within each drug comparison of interest. Based on a recommendation from the TEP, we did not combine data on different types of fracture; hence we report findings for total fractures only if a study reported data on total fractures (likewise for non-vertebral fractures). The primary outcome for our efficacy analysis is the number of people who reported at least one fracture. Because the occurrence of a fracture was fairly rare, and zero events were often observed in at least one of the treatment groups, odds-ratios (OR) were calculated using the Peto method. ^32^ An OR with a value less than one indicates that the odds of having a fracture is less in the intervention group than in the comparison group. Trials that report zeros in both groups have an undefined OR. Because fractures are rare events, the OR approximates the relative risk (RR) of fracture. In some instances, we combined data from multiple study arms in an individual study to calculate a single OR for comparisons of interest. In these instances, the same outcome had been reported for each of the arms, and the individuals in each arm were unique. For example, to develop on OR for the risk of vertebral fractures regardless of dose, subjects in the various dose groups were combined and compared with subjects in the placebo group.

Among comparisons that had not previously been pooled in other meta-analyses and that had at least three trials that were judged to be clinically similar enough to warrant meta-analysis, we estimated a pooled OR using the Peto method. ^32^ When analyzing outcomes with rare events, the Peto method has been shown to give the least biased estimate. ^33^ Forest plots are provided when trials were pooled. The OR for each trial is illustrated by a box, where the size of the box is proportional to the trial's sample size. The 95% confidence interval (CI) is depicted as a horizontal line on each side of the box. A diamond on the bottom of each graph represents the pooled estimate and CI. A vertical solid line at one indicates no treatment effect.

We also report the chi-squared test of heterogeneity p-value based on Cochran's Q ^34^ and the I^2^ statistic. ^35^ A significant Q statistic or I^2^ values close to 100% represent very high degrees of heterogeneity. I^2^ values of 25%, 50%, and 75% represent low, moderate, and high heterogeneity.

All efficacy meta-analyses were conducted with Stata statistical software. ^36^

Recognizing that the risk of fracture may be affected by characteristics of the study population, we defined risk groups for fracture and assigned each of the controlled clinical trials to one risk group. Published meta-analyses that are summarized in this report typically used similar criteria to define risk groups, which we detail in the tables summarizing the meta-analyses. The criteria we used to define risk groups are as follows:

High-risk:

1) transplant population, or
2) study entry criteria require T score ≤ -2.5, or
3) study entry criteria require ≥1 fracture, or
4) ≥50% population has 1 or more fractures at baseline or
5) Significant neuromuscular impairment

Intermediate-risk:

1) study entry criteria require T score ≤1.5, or
2) 10–49.99% of population has one or more fracture at baseline, or
3) study population has chronic disease that is commonly treated with glucocorticoids or
4) in the absence of data on BMD or fractures, mean age of population ≥ 62 years.

Low-risk:

1) study entry criteria require T score ≤0.0, or
2) < 10% of population has BMD =8 g/cm2 at baseline, or
3) < 10% of population has one or more fracture at baseline, or
4) in the absence of data on BMD or fracture, mean age of population <62 years.

Unknown risk:

BMD, fracture history, and age not reported as entry criteria or in baseline characteristics of population.

### Adherence

The term adherence is defined as the extent to which a person's health behavior is consistent with medical advice. ^37^ Health behavior refers not only a patient's decision to take a medication at the prescribed frequency, but also to their conformity to recommended dosages, timing (e.g., each morning, 30 minutes prior to eating), and instructions (e.g., with or without food, remain upright for 1 hour, etc.). Adherence is synonymous with the term compliance. Persistence is defined as the duration of treatment, while nonpersistence is defined as treatment discontinuation without medical recommendation. ^37^

A qualitative summary of the literature on adherence and persistence with medications for osteoporosis was developed focusing on 1) the effect of adherence and persistence of medications for osteoporosis on fractures, 2) rates of adherence and persistence of medications to treat or prevent osteoporosis, and 3) the factors that affect adherence and persistence of medications to treat or prevent osteoporosis.

### Adverse Events

Two main analyses were performed for adverse events: analyses to assess the relationship between a group of adverse events that were identified a priori as particularly relevant and exploratory analyses of all adverse events that were reported for any of the drugs. For the analyses of adverse events, we examined (where possible given the available data) comparisons of drug versus placebo, and comparisons of drug versus drug, for drugs within the same class and across classes.

A list of all unique adverse events that were reported in any of the studies was compiled, and a physician grouped adverse events into clinically sensible categories and subcategories, including a category for each of the adverse events that were identified a priori as being of interest. For groups of events that occurred in three or more trials, we performed a meta-analysis to estimate the pooled OR and its associated 95% confidence interval. Given that many of the events were rare, we used exact conditional inference to perform the pooling rather than applying the usual asymptotic methods that assume normality. Asymptotic methods require corrections if zero events are observed; generally, half an event is added to all cells in the outcome-by-treatment (two-by-two) table in order to allow estimation, because these methods are based on assuming continuity. Such corrections can have a major impact on the results when the outcome event is rare. Exact methods do not require such corrections. We conducted the meta-analyses using the statistical software package StatXact Procs for SAS Users. ^38^ For events that were reported in only one trial, an OR is calculated and reported.

Any significant OR greater than one indicates the odds of the adverse event associated with the bone density drug is larger than the odds associated with an adverse event among patients in the comparison group (placebo, vitamin D, estrogen, calcium, or other bone density drug). We note that if no events were observed in the comparison group, but events were observed in the intervention group, the OR is infinity and the associated confidence interval is bounded from below only. In such a case, we report the lower bound of the confidence interval.

## Peer Review

A draft version of the report was submitted for peer review and public comment in May, 2006. This final report includes the revisions and additional analyses conducted in response to those comments.