# 1 Introduction

## Background

Osteoporosis (OP) is a systemic skeletal disease characterized by low bone mass and microarchitectural deterioration of bone tissue, with a consequent increase in bone fragility and susceptibility to fracture. ^1^ Approximately 44 million people in the United States are affected by OP and low bone mass. ^2^ The clinical complications include fractures, disability, and chronic pain. It is estimated that 54% of women age 50 and older will sustain an osteoporotic fracture during their lifetime. ^3^ Further, approximately 4% of patients older than 50 who experience a hip fracture will die while in the hospital, and 24% will die within a year after experiencing the hip fracture. ^4^

The economic burden of OP is large and growing. Most estimates are based on the cost of fracture alone: A 1995 estimate of costs due to osteoporotic fracture in the United States produced a figure of $13.8 billion. ^5^ A 2003 review estimated the total costs in the United States at $17 billion. ^6^ Although the bulk of these costs were incurred by individuals older than 65 who are retired, direct costs and work-loss are significant among employed postmenopausal women. ^7^ The increasing prevalence and cost of OP has heightened interest in the efficacy and safety of the many agents currently available to treat the loss of bone mineral associated with osteoporosis.

## Definition of Osteoporosis

The clinical definition of osteoporosis is based either on clinical evidence of fracture or on densitometric measurement of bone mineral density (expressed as grams [gms] per centimeter [cm]^2^). The National Osteoporosis Foundation (NOF) defines osteoporosis as a disease characterized by increased bone fragility and risk for fracture; of special concern are fractures of the hip and spine. ^8^ The World Health Organization (WHO) defines osteoporotic bone as bone that is more than 2.5 standard deviations lower in BMD than that of the average 25-year-old adult (called the young-adult mean). ^a^ ^9^ Thus, the number of standard deviations below normal, also known as the T-score (e.g., a T-score of -1 indicates a BMD that is 1 SD below the young-adult mean) can be used to define osteoporosis. Osteopenia, considered a precursor to osteoporosis, is defined as a T-score between -1 and -2.5. (WHO). Severe osteoporosis can be defined as a BMD of -2.5 or below that is accompanied by at least one fragility fracture (NOF).

a Because the majority of the population used to derive this average consisted of white females and because it is known that bone density differs between men and women (a difference that increases with age past 50) as well as among whites, blacks, and people of Asian origin, some concern exists regarding its application to men and to nonwhites.

Osteoporosis can be further categorized based on its etiology. Primary, or involutional, osteoporosis, the most common form, is applied to any diagnosis in which a disease or disorder known to result in osteoporosis is not present. Primary osteoporosis can be further categorized as juvenile, postmenopausal, age-related, and idiopathic (diagnosed in a young adult with no known contributing disorder) osteoporosis. Secondary osteoporosis is diagnosed when the cause of the bone loss can be attributed to another disease or use of particular types of medication, as described below.

## Risk Factors for Low BMD, Osteoporosis, and Fractures

Osteoporosis is a major cause of morbidity and mortality in older persons. The difficulty and cost of treating osteoporosis necessitate developing a method to identify those who are most at risk and therefore candidates for preventive interventions. However, whereas low BMD is associated with an increased risk for fracture, it is not a perfect predictor. Further, clinical risk factors alone do not adequately predict low BMD. Current evidence does not support the use of densitometry as a screening tool for low risk population because of its cost, as well as its inability to predict who will sustain fractures. ^10^ However, when its use is restricted to those with known risk factors for low BMD and fracture, its prognostic value improves.

Of additional concern is the relationship between bone mineral density (BMD) and fracture risk, which is imperfect. While loss of bone mineral is associated with an increased risk of fracture, it is not a perfect predictor. Nevertheless, several agents for treatment of OP and all agents indicated for prevention of OP have been approved based on data on their ability to preserve or increase BMD. Thus, it is important to evaluate the evidence regarding the effect of these drugs on fracture risk.

### Risk Factors for Low BMD and Osteoporosis

The major risk factors for osteoporosis include age, sex, body size, lifestyle, and family history. Peak bone mass is achieved by late adolescence and maintained throughout the 20s, 30s, and 40s with adequate intakes of calcium and vitamin D and exercise. Bone loss begins to accelerate after the age of 50, particularly in postmenopausal women. ^11^ Low body weight, loss of weight (in older individuals), sedentary lifestyle, and a history of anorexia nervosa or athletic amenorrhea increase the risk for osteoporosis. Additional factors that are associated with an increased risk for osteoporosis include having a disease that requires treatment with glucocorticoids, family history of bone disease, and hypogonadism (in men). The design and validation of risk assessment tools is an active area of research. ^12^

### Risk Factors for Fracture

The evidence supporting a link between a large number of potential factors and risk for fracture was reviewed in a 2001 meta-analysis. ^10^ The outcome assessed in the majority of studies was hip fracture. The following factors had the strongest predictive value for fracture risk (as evidenced by a RR greater than 2.00): older age (older than 70–80); low body weight or body mass index or loss of weight; prior osteoporotic fracture; use of glucocorticoids; use of the older anticonvulsants (that interfere with vitamin D metabolism); sedentary lifestyle; primary hyperparathyroidism; type I diabetes; anorexia nervosa; gastrectomy; pernicious anemia; and male hypogonadism. Menopause and family history of osteoporotic fracture were moderate risk factors. Caveats discussed by the authors were that various populations have not been studied equally; most studies included only whites and only persons older than 50; and only half of the studies included men. Additional meta-analyses on the effects of alcohol and of smoking on fracture risk identified a considerable increase in risk that could not be attributed to BMD. ^10,^ ^13,^ ^14^

### The Role of Falls

Osteoporotic fractures are sustained through falls. Thus, it is also important to consider the factors that increase the risk for falling, particularly among elderly people, and the evidence base for fall management.

The risk for falling increases with age, as do the consequences. Among community-dwelling elderly, five percent of falls result in a fracture or other cause for hospitalization. In nursing homes and hospitals, the risk for falling and the risk for complications are considerably higher: 10 to 25 percent of institutional falls result in fracture, laceration, or other need for hospital care. The most important risk factors for falls are gait and balance disorders, functional impairment, visual deficits, cognitive impairment, and use of psychotropic medications. ^15^ – ^18^ When these factors are combined, the effect on falls is synergistic.

## Treatment and Prevention of Osteoporosis

For individuals identified to be at risk for developing osteoporosis, intervention measures are aimed at preventing the condition from developing, whereas in those who have already presented with low BMD or fractures, treatment is aimed at preventing further bone loss to reduce the risk of initial or subsequent fracture.

The NOF has issued a set of evidence-based guidelines for the diagnosis, treatment, and prevention of osteoporosis; first issued in 1999, the guidelines have since been updated. ^8^ Prevention recommendations include adequate intakes of calcium and vitamin D, maintenance of regular weight-bearing exercise, fall prevention, and avoidance/limitation of tobacco and alcohol use. Several of these recommendations are discussed in greater detail below. Indications and recommendations for pharmacologic treatment are also included in the guidelines. The NOF recommends pharmacologic intervention for women with T-scores of -2.0 or less but with no other risk factors; for women with T-scores of -1.5 or less with other risk factors; and for any woman with a prior vertebral or hip fracture. Treatment methods are discussed below.

### Nutrition and Use of Supplements

Although many nutrients are involved in bone formation and maintenance, calcium and vitamin D appear to play the most central role. In 1997, as part of the periodic update of the recommended dietary allowances (RDAs, now known collectively as the dietary reference intakes or DRIs), the Institute of Medicine systematically reviewed the literature on nutrition and bone health and developed a set of evidence-based recommendations for intake of calcium and vitamin D. This review also found that the average American does not consume a diet that is adequate in calcium and that many Americans, especially those at highest risk for osteoporotic fractures, do not obtain adequate vitamin D from the diet or through sun exposure. ^19^ Thus, the Surgeon General's Report on Bone Health and Osteoporosis, among others, recommends the routine use of calcium and vitamin D supplements.

### Physical Activity and Falls Prevention

Physical activity contributes to the reduction of fracture risk in two ways. First, the biomechanical pull of muscles on bones has been shown to increase bone density; thus, weight-bearing exercise appears to play an important role in increasing and preserving bone mass. Second, regular physical activity has been shown to help prevent falls due to balance problems and decreased strength and endurance. Recommendations for management of falls consist of measures aimed at detection, evaluation, and intervention. ^20^ The Surgeon General's Report on Bone Health and Osteoporosis recommends strength and weight-bearing activities in addition to 30 minutes per day of regular exercise.

### Pharmacologic Agents Other Than Supplements

Various pharmaceutical agents have been approved by the Food and Drug Administration (FDA) for the treatment and/or prevention of osteoporosis. This section provides a brief review of the FDA approval process for agents intended to treat and prevent osteoporosis and its relationship to fracture prevention, followed by a description of the agents that have received FDA approval.

The FDA Approval Process. In 1979, the FDA published its first guidance document for the clinical evaluation of the safety and efficacy of drugs to treat osteoporosis. ^21^ From the outset, the FDA acknowledged certain difficulties, including quantitative assessment of skeletal bone, the inexact relationship between bone mass and fracture risk, and the size and duration of studies that would be required to detect changes in bone density and/or fracture risk. Inclusion criteria for clinical trials were defined as objective evidence of disease (that is, history of an osteoporosis-related fracture) or the less objective criterion of low bone mass, as determined by any one of six methods, all imperfect. In an effort to ease the process of trial implementation, the Guidance Document permitted efficacy to be defined as improvement in bone mass during therapy if the process of new bone formation could be demonstrated to be normal, rather than requiring evidence of significant decrease in fracture risk. If new bone formation did not prove normal or if it was not possible to determine normalcy, fracture studies would be required.

Operating under the initial guidance document—which did not require demonstration of fracture risk reduction—calcitonin was approved as an injectable drug for the treatment of osteoporosis in 1984, conditional upon the initiation and eventual completion of a trial to assess fracture risk. Calcitonin is a peptide hormone synthesized in the thyroid that participates in the physiological regulation of calcium and phosphorus; it had previously been approved for the treatment of Paget's disease (a disease characterized by abnormal bone remodeling). Upon completion of the study, it became apparent that enrollment and retention of patients in this fracture trial was problematic, and the fracture reduction efficacy of calcitonin remained in doubt. In the early 1990s, the Prevent Reoccurrence of Osteoporotic Fracture (PROOF) trial tested the ability of a nasally administered form of calcitonin (100, 200, and 400 IU) to prevent fracture. Although fracture prevention was seen with 200 IU, none was seen at the higher or lower dose; this lack of dose response, combined with a lack of effect on BMD suggested either that the positive effect of the 200 IU dose was an artifact or that BMD and fracture risk are not well correlated. Nevertheless, the drug is still widely prescribed.

During the 1980s, two additional agents-sodium fluoride (NaF) and the bisphosphonate (see below) etidronate—were evaluated for the treatment of osteoporosis under the initial guidance document, which did not require fracture risk reduction. Although both agents increased bone density significantly when tested in large scale trials of postmenopausal women, evidence suggested that neither reduced the risk for vertebral fracture and that at least one (NaF) may have increased fracture risk. Based on this experience, the Osteoporosis Guidance document was updated in 1994 to include the following requirements for approval of a new drug to treat postmenopausal osteoporosis: 1) demonstration of normal bone quality in preclinical studies with two laboratory animal species, including the ovariectomized rat model; 2) normal bone quality in a subset of clinical trial participants; 3) significant increase in BMD; and 4) at least a positive trend in 3-year fracture risk decrease. The 1994 Guidance document also provided requirements for approval of agents for prevention of osteoporosis (in individuals at high risk but without history of osteoporotic fracture). Only agents that have already been approved for treatment of osteoporosis can be approved for prevention. For prevention, BMD may serve as an appropriate-and sufficient-outcome measure for efficacy in double-blind RCTs of at least 2 years duration with multiple dosage arms (to establish a minimum effective dose). The guidance also provided recommendations for the appropriate sample population.

Based on extensive data from observational studies, estrogen was exempted from the fourth requirement and was approved for prevention based on BMD alone. Subsequently, however, the FDA has required evidence of fracture efficacy for approval of selective estrogen receptor modulators (SERMS). In 1997, the first SERM, raloxifene, was approved. The bisphosphonate alendronate was the first nonestrogenic agent to be evaluated and approved for treatment of postmenopausal osteoporosis.

In 2004, the FDA began soliciting comments on the 1994 Guidance document in preparation for its revision. Two issues of particular interest were the continued use of placebo (as opposed to active) controls (an issue with both ethical and technical implications) and the minimum acceptable duration for treatment trials.

Thus, not all drugs currently approved for treatment of osteoporosis were required to demonstrate reduction in fracture risk (e.g., calcitonin). With the exception of estrogen products all agents approved for prevention of osteoporosis have demonstrated fracture reduction, as they were approved first for osteoporosis treatment. Further, approval of an indication for a different dose, frequency, or route of administration does not require demonstration of reduced fracture risk. These implications of the current guidance have heightened interest in evaluating the efficacy data for drugs approved to treat and prevent osteoporosis.

The Agents. The agents currently approved for treatment and/or prevention of osteoporosis include bisphosphonates; hormone replacement therapy with estrogen or combination estrogen/progesterone preparations; calcitonin; raloxifene; and parathyroid hormone. In addition, testosterone has been tested but is not approved for this indication.

Bisphosphonates are compounds that permanently bind to mineralized bone surfaces and disrupt bone resorption by at least two different mechanisms. The non-nitrogenous bisphosphonate etidronate is taken up by osteoclasts (the cells responsible for resorption), where it competes with ATP, inducing apoptosis (programmed cell death). The nitrogenous bisphosphonates alendronate, ibandronate, pamidronate, risedronate, and zoledronic acid inhibit a step in the HMG CoA Reductase pathway (the enzymatic pathway responsible for cholesterol synthesis), resulting in the disruption of attachment of several subcellular proteins to the cell membrane. Other mechanisms implicated in bisphosphonates' inhibition of bone resorption include interference with cytoskeletal lipoproteins. Bisphosphonates approved by the FDA for both treatment and prevention of osteoporosis are alendronate, ibandronate, and risedronate (see Table 1 for dosages). Alendronate and risedronate are approved for treatment of men with osteoporosis as well as men and women with glucocorticoid-induced osteoporosis. Etidronate, pamidronate, and zoledronic acid are not approved for the prevention or treatment of osteoporosis, but are used off-label for this purpose. Several other bisphosphonates, such as tiludronate and clodronate, have been tested in clinical trials of osteoporosis but are not yet approved for the treatment of osteoporosis in the United States. Therefore, they will not be reviewed at this time.

Table 1 FDA-approved indications for agents used to prevent or treat osteoporosis by BMD and fracture data used for approval or detailed in package inserts

Calcitonin is a peptide hormone produced by the follicular cells of the thyroid gland that suppresses osteoclast activity. As described above, calcitonin was approved for the treatment of osteoporosis prior to the requirement for demonstration of reduction in fracture risk. Calcitonin is available in several forms for different routes of administration.

SERMs exhibit a pharmacologic profile characterized by estrogen agonist activity in some tissues with estrogen antagonist activity in other tissues. ^22^ The first widely used SERM, tamoxifen, has estrogen antagonist activity in breast tissue and is approved for treatment of breast cancer. Another SERM, raloxifene, exhibits an estrogen agonist profile in the skeletal system. This agent is FDA-approved for the prevention and treatment of postmenopausal osteoporosis.

One of the newest treatments for osteoporosis is human parathyroid hormone (PTH), which helps to regulate calcium metabolism and promotes the growth of new bone. Two analogs of human PTH have been developed for use in the treatment of osteoporosis. Teriparatide (brand name Forteo) is a synthetic form of the first 34 amino acids of human PTH (PTH 1–34). This drug is administered by injection and is FDA-approved for up to 24 months of use for the treatment of osteoporosis among postmenopausal women and hypogonadal men. Full-length PTH (brand name PReOs) contains all 84 amino acids in human PTH (PTH 1–84). This agent is under review for FDA approval. Because it is not FDA-approved, full-length PTH is not reviewed in this report.

Adherence to Treatment. In spite of demonstrated efficacy in clinical trials, the effectiveness of medications in daily clinical practice is affected by adherence (also known as compliance) and persistence. It is well established that long-term adherence to medication regimens for many chronic diseases such as hypertension, ^23,^ ^24^ and hyperlipidemia ^25,^ ^26^ is inadequate. This knowledge, coupled with concerns regarding the side-effect profile of some treatments for osteoporosis, led to interest in assessing what is known about adherence to these treatments in daily practice.

## This Report

Under Section 1013 of the Medicare Modernization Act, the Agency for Healthcare Research and Quality (AHRQ) was instructed to conduct comparative-effectiveness reviews (CER) on medications, devices, and other interventions. The CERs aim to concisely synthesize the evidence, clearly state conclusions about the evidence, and identify research gaps.

This CER compares the benefits in fracture reduction and the harms from adverse events (AE) among and within the various classes of treatment for low bone density. Our outcomes of interest for measuring benefits are vertebral, non-vertebral, hip, and radial fractures. The studies collect vertebral fracture outcomes in one of two ways. In some studies, all participants undergo radiography at pre-determined intervals. Other studies use clinical criteria, i.e. whether a fracture has been diagnosed by a clinician during the time interval. Trials that radiograph all participants will by nature detect more fractures. However the higher detection rate will apply to both treatment and placebo groups. Thus, the relative differences found should be similar that found in studies that use clinical criteria.

To characterize harms, we examine cardiac, dermatologic, endocrine, gastrointestinal, genitourinary, hematological, immunologic, metabolic, musculoskeletal, neurological, psychiatric, and respiratory adverse events armory the treatment and placebo groups.

Table 1 describes current FDA-approved indications and the evidence base for these indications for the treatments evaluated in this review.

## Scope and Key Questions

Key Question 1. What are the comparative benefits in fracture reduction (including vertebral and nonvertebral sites [hip, radius, and proximal humerus]) among and also within (particularly for parts a and b) the following treatments for low bone density:

a Bisphosphonate medications, specifically: alendronate, risedronate, etidronate, ibandronate, pamidronate, and zoledronic acid; and between intravenous and orally administered forms
b Selective estrogen receptor modulators, specifically: raloxifene and tamoxifen
c Calcitonin
d Parathyriod hormone (PTH)
e Testosterone for men
f Estrogen for women
g Calcium
h Vitamin D in comparison to alternate therapies ^b^
  b Will summarize recent meta-analyses on vitamin D, but will not search for, evaluate, or summarize individual studies on vitamin D unless vitamin D is a comparator arm in studies of other drugs noted above.
i Exercise in comparison to alternate therapies
j Combinations of above

Key Question 2. How does fracture reduction resulting from treatments vary between individuals with different risks for fracture as determined by bone mineral density (borderline/low/severe), prior fractures (prevention vs. treatment), age, gender, glucocorticoid use, and other factors (e.g., community dwelling vs. institutionalized; vitamin D deficient vs. not)?

Key Question 3. What are the adherence to and persistence with medications for the treatment and prevention of osteoporosis, the factors that affect adherence and persistence and the effects of adherence and persistence on the risk of fractures?

Key Question 4. What are the short- and long-term harms (adverse effects) of the above therapies, and do these vary by any specific subpopulations?